# References

1 Murphy KM, Topel RH. (2003). The Economic Value of Medical Research. Murphy KM, Topel RH, editors. Measuring the Gains from Medical Research: An Economic Approach.
2 Cheng Y, Berry DA. (2007). Optimal adaptive randomized designs for clinical trials. Biometrika.
3 Stinnett AA, Mullahy J. (1998). Net health benefits: a new framework for the analysis of uncertainty in cost-effectiveness analysis. Med Decis Making.
4 Eckermann S, Willan AR. (2009). Globally optimal trial design for local decision making. Health Econ.
5 Meltzer D. (2001). Addressing uncertainty in medical cost-effectiveness analysis: implications of expected utility maximization for methods to perform sensitivity analysis and the use of cost-effectiveness analysis to set priorities for medical research. J Health Econ.
6 Drummond MF, Davies L. (1991). Economic analysis alongside clinical trials. Revisiting the methodological issues. Int J Technol Assess Health Care.
7 Meltzer DO, Basu A, Meltzer HY. (2009). Comparative effectiveness research for antipsychotic medications: how much is enough?. Health Aff.
8 Detsky AS. (1985). Using economic analysis to determine the resource consequences of choices made in planning clinical trials. J Chronic Dis.
9 Willan AR. (2008). Optimal sample size determinations from an industry perspective based on the expected value of information. Clin Trials.
10 Janssen MP, Koffijberg H. (2009). Enhancing value of information analyses. Value Health.
11 Detsky AS. (1990). Using cost-effectiveness analysis to improve the efficiency of allocating funds to clinical trials. Stat Med.
12 Townsend J, Buxton M, Harper G. (2003). Prioritisation of health technology assessment. The PATHS model: methods and case studies. Health Technol Assess.
13 Ramsey SD, Blough DK, Sullivan SD. (2008). A forensic evaluation of the National Emphysema Treatment Trial using the expected value of information approach. Med Care.
14 Girling AJ, Freeman G, Gordon JP, et al. (2007). Modeling payback from research into the efficacy of left-ventricular assist devices as destination therapy. Int J Technol Assess Health Care.
15 Stevenson MD, Scope A, Sutcliffe PA. (2010). The cost-effectiveness of group cognitive behavioral therapy compared with routine primary care for women with postnatal depression in the UK. Value Health.
16 Omenn GS. (2001). Assessment of human cancer risk: challenges for alternative approaches. Toxicol Pathol.
17 Willan AR, Pinto EM. (2005). The value of information and optimal clinical trial design. Stat Med.
18 Eckermann S, Willan AR. (2007). Expected value of information and decision making in HTA. Health Econ.
19 Willan A, Kowgier M. (2008). Determining optimal sample sizes for multi-stage randomized clinical trials using value of information methods. Clin Trials.
20 Willan AR, Eckermann S. (2010). Optimal clinical trial design using value of information methods with imperfect implementation. HealthEcon.
21 Willan AR. (2007). Clinical decision making and the expected value of information. Clin Trials.
22 Barton GR, Briggs AH, Fenwick EA. (2008). Optimal cost-effectiveness decisions: the role of the cost-effectiveness acceptability curve (CEAC), the cost-effectiveness acceptability frontier (CEAF), and the expected value of perfection information (EVPI). Value Health.
23 Fenwick E, Marshall DA, Blackhouse G, et al. (2008). Assessing the impact of censoring of costs and effects on health-care decision-making: an example using the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Value Health.
24 Groot Koerkamp B, Nikken JJ, et al. (2008). Value of information analysis used to determine the necessity of additional research: MR imaging in acute knee trauma as an example. Radiology.
25 Groot Koerkamp B, Spronk S, et al. (2010). Value of information analyses of economic randomized controlled trials: the treatment of intermittent claudication. Value Health.
26 Forbes C, Wilby J, Richardson G, et al. (2002). A systematic review and economic evaluation of pegylated liposomal doxorubicin hydrochloride for ovarian cancer. Health Technol Assess.
27 National Institute for Health and Clinical Excellence. Guide to the methods of technology appraisal 2008.
28 Dutch Health Care Insurance Board (CVZ). Guidelines for pharmacoeconomic research, updated version.
29 Dutch Health Care Insurance Board (CVZ). Leidraad uitkomstenonderzoek ‘ten behoeve van de beoordeling doelmatigheid intramurale geneesmiddelen’: [in Dutch].
30 Smith DH, Drummond MF, Johnston S, et al. (2001). Economic evaluation of liposomal doxorubicin versus topotecan for recurrent ovarian cancer in the UK. Value in Health.
31 Skwarski K, MacNee W, Wraith PK, et al. (1991). Predictors of survival in patients with chronic obstructive pulmonary disease treated with long-term oxygen therapy. Chest.
32 Honey KL, Bennett P, Morgan M. (2002). A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol.
33 Siegenthaler MP, Westaby S, Frazier OH, et al. (2005). Advanced heart failure: Feasibility study of long-term continuous axial flow pump support. Eur Heart J.
34 Hutton EK, Kaufman K, Hodnett E, et al. (2003). External cephalic version beginning at 34 weeks’ gestation versus 37 weeks’ gestation: a randomized multicenter trial. Am J Obstet Gynecol.
35 Tannock IF, Osoba D, Stockler MR, et al. (1996). Chemotherapy with mitoxantrone plus prednisone or prednisone alone for symptomatic hormone-resistant prostate cancer: a Canadian trial with palliative endpoints. J Clin Oncol.
36 Bloomfield DJ, Krahn MD, Neogi T, et al. (1998). Economic evaluation of chemotherapy with mitoxantrone plus prednisone for symptomatic hormone-resistant prostate cancer: based on a Canadian trial with palliative endpoints. J Clin Oncol.
37 Goeree R, O’Brien BJ, Blackhouse G, et al. (2002). Cost-effectiveness and cost-utility of long-term management strategies for heartburn. Value Health.
38 Nikken JJ, Oei EH, Ginai AZ, et al. (2005). Acute peripheral joint injury: cost and effectiveness of low-field-strength MR imaging—results of randomized controlled trial. Radiology.
39 Spronk S, Bosch J, den Hoed P, et al. (2008). Cost-effectiveness of endovascular revascularization compared to supervised hospital-based exercise training in patients with intermittent claudication: a randomized controlled trial. J Vasc Surg.
40 Chiba N, van Zanten SJ, Sinclair P, et al. (2002). Treating Helicobacter pylori infection in primary care patients with uninvestigated dyspepsia: the Canadian adult dyspepsia empiric treatment—Helicobacter pylori positive (CADET-Hp) randomised controlled trial. BMJ.
41 Marple BF, Roberts CS, Frytak JR, et al. (2010). Azithromycin extended release vs amoxicillin/clavulanate: symptom resolution in acute sinusitis. Am J Otolaryngol.
42 (2010). Drug Topics Red Book.
43 Tolley G, Babcock L, Berger M, et al. (1986). Valuation of reductions in human health symptoms and risk, Contingent valuation study of light symptoms and angina.
44 Jemal A, Siegel R, Ward E, et al. (2007). Cancer Statistics, 2008. CA Cancer J Clin.
45 Cascinu S, Graziano F, Catalano G. (1999). Chemotherapy for advanced pancreatic cancer: It may no longer be ignored. Ann Oncol.
46 Moore MJ, Goldstein D, Hamm J, et al. (2007). Erlotinib plus gemcitabine compared with gemcitabine alone in patients with advanced pancreatic cancer: a phase III trial of the National Cancer Institute of Canada Clinical Trials Group. J Clin Oncol.
47 Altekruse SF, Kosary CL, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975–2007.
48 Danese MD, Reyes C, Northridge K, et al. (2008). Budget impact model of adding erlotinib to a regimen of gemcitabine for the treatment of locally advanced, nonresectable or metastatic pancreatic cancer. Clin Ther.