# Peer Reviewers

Mark Helfand, M.D., M.S., M.P.H.

Director, Oregon Evidence-based Practice Center

Oregon Health and Sciences University

Portland, OR

Evan Myers, M.D., M.P.H.

Chief of the Division of Clinical and Epidemiological Research

Department of Obstetrics and Gynecology

Duke University

Durham, NC

Gillian Sanders, Ph.D.

Associate Professor of Medicine

Duke University

Durham, NC

Tom Trinkalos, M.D.

Tufts Evidence-based Practice Center

Tufts University

Boston, MA