# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: We wish to thank Justine Seidenfeld for excellent research assistance.