# Literature Review

We conducted a comprehensive review of both published, peer-reviewed literature and grey literature to identify and describe clinical research studies describing or applying minimal modeling approaches to VOI.

## Search Strategy and Inclusion Criteria

We searched the MEDLINE database for English-language publications from January 1, 1990 to June 3, 2010, using the following exact search terms (in all fields): “value of information,” “value of additional information,” “value of information analysis,” “expected value of perfect information,” “EVPI,” “expected value of partial perfect information,” “EVPPI,” “Bayesian approach to uncertainty,” or “value of research.” All titles and abstracts of the search results were screened by two investigators (DM and JC) to identify potentially relevant studies.

Our grey literature search was limited to Internet sites of different health technology assessment (HTA) organizations and institutions in the United States, Canada, the U.K., Australia/New Zealand, The Netherlands, and Germany. Websites were searched for: (1) VOI methods guidance intended to aid authors in completing a HTA, and (2) examples of VOI applications in individual HTA and systematic review publications.

Studies were only included if they involved clinically related application or development of VOI analysis for estimating the value of research or prioritization of research. Studies focusing on the value of diagnostic testing to collect information to guide the treatment for individual patients did not meet our scope definition, and were not included in our review. In addition, the reference lists of relevant studies were checked.

## Study Classification and Data Extraction

Based on the full-text reading, the investigators (DM, TH, JC, and AB) independently classified the publications as to whether (1) these involved “VOI theory/methods only,” “VOI theory/methods with application,” or “VOI application only,” and (2) whether the approach to the VOI calculations comprised the use of a full model, limited modeling, or no modeling (Table 1).

We summarized theory and methods for those studies that appeared to adopt a minimal modeling approach. For each VOI application in the studies that were classified “VOI theory/methods with application” or “VOI application only” based on a “limited modeling” or “no modeling” approach, we extracted data on: the limited modeling component; the approach to VOI calculations (Table 1); the application and its setting; the perspective of analysis; the incidence (or prevalence) of the disease or condition; the time horizon of the decision problem (relating to durability); the approach (if any) to implementation issues; the discounting of costs and effects; and the cost-effectiveness results and VOI results (per patient and per population).

All data extraction was done by one investigator (TH), while the other investigators (DM, JC, and AB) performed a check for accuracy and completeness of the extracted data. Any disagreements about the classification of publications and the data extraction were resolved by consensus. We undertook a descriptive synthesis of the review results and compared VOI calculations across studies.

## Results

### Identification of Studies

Figure 1 is a flowchart that summarizes the process and results of our literature review. The MEDLINE database search produced 230 hits, while 120 studies were identified as potentially relevant following the screening of the abstracts and titles. On the basis of full-text reading of the 116 papers that we were able to collect, we identified 18 studies as “VOI theory/methods only,” and 80 studies with some empirical application, including 24 studies with “VOI theory/methods with application(s)” and 56 “VOI application only.” In total, we found 4 studies describing minimal modeling approaches only,5, 8–10 while 8 VOI applications adopting a limited modeling approach were reported in 6 studies7,11, 12[a,b,c],13–15 versus 9 VOI applications with no modeling in 12 studies.4,16, 17[a,b], 18, 19[a,b], 20 [a,b]; 21–25

Figure 1 VOI literature review flowchart

Figure 1 is a flow chart that summarizes the search and selection of articles from the VOI literature for the review. It begins with the total number of hits screening from both a MEDLINE search and a gray literature search, and ends with the number of studies that were included as each VOI category in the report. This figure is described further in the Section titled “Results, Identification of Studies” as follows: “Figure 1 is a flowchart that summarizes the process and results of our literature review. The MEDLINE database search produced 230 hits, while 120 studies were identified as potentially relevant following the screening of the abstracts and titles. On the basis of full-text reading of the 116 papers that we were able to collect, we identified 18 studies as “VOI theory/methods only,” and 80 studies with some empirical application, including 24 studies with “VOI theory/methods with application(s)” and 56 “VOI application only.” In total, we found four studies describing minimal modeling approaches only (references 5 and 8–10) while eight VOI applications adopting a limited modeling approach were reported in 6 studies (references 7,11, 12, and 13–15) versus 9 VOI applications with no modeling in 12 studies. (references 4, 16–25). In our grey literature search, 12 HTA organizations were identified, with only two organizations (i.e., NICE in the U.K. and CVZ in The Netherlands) providing a small amount of guidance for the use of VOI methods. A search of all HTA publications from these organizations for VOI analysis produced 22 hits, nine of which were previously identified in the MEDLINE search. Of the 13 new publications, we classified 12 as full VOI models, and one as minimal modeling with one application. Table 2 summarizes these searches by country.

In our grey literature search, 12 HTA organizations were identified, with only 2 organizations (i.e., NICE in the U.K. and the Dutch Health Care Insurance Board [CVZ] in The Netherlands) providing a small amount of guidance for the use of VOI methods. A search of all HTA publications from these organizations for VOI analysis produced 22 hits, 9 of which were previously identified in the MEDLINE search. Of the 13 new publications, we classified 12 as full VOI models, and one as minimal modeling with one application.26 Table 2 summarizes these searches by country.

Table 2 Results of grey literature search, by country

Country | Search & Results
United States | We searched publications of the VA Technology Assessment Program and the Agency for Healthcare Research and Quality Effective Health Care Program, but identified no relevant VOI studies
United Kingdom | We searched NICE reports. The use of VOI analysis is advocated in published methods guidance.27 Four technology appraisals used full modeling approaches for VOI calculations. One uses minimal modeling approaches and is included. Three full modeling VOI studies but no minimal modeling studies were identified in publications of the U.K. National Institute for Health Research Health Technology Assessment Program.
Canada | Five full-model VOI studies and no minimal-model studies were found among the publications of the Canadian Agency for Drugs and Technologies in Health Health Technology Assessment Program. Searches at the PATH Research Institute and Ontario Health Technology Assessment Series revealed no VOI studies.
Australia | Reports of the Medical Services Advisory Committee at the Australian Department of Health and Ageing, the Australian Safety and Efficacy Register of New Interventional Procedures - Surgical based in the Royal Australasian College of Surgeons produced no VOI studies.
New Zealand | Reports of Health Services Assessment Collaboration at the University of Canterbury funded by the New Zealand Ministry of Health produced no VOI studies.
The Netherlands | Reports of The Netherlands Organisation for Health Research and Development, which executes many reports funded by the Ministry of Health and The Netherlands Organisation for Scientific Research, included no VOI studies. Reports of the Dutch Health Care Insurance Board (CVZ) included guidance on uncertainty analysis in economic evaluation 28,29 that could include VOI but no full or minimal modeling VOI studies.
Germany | Reports of the German Institute for Quality and Efficiency in Health Care, which works under contract from the Federal Joint Committee and the Federal Ministry of Health, revealed no VOI studies.

### Theory/Methods on Minimal Modeling

Four papers described theory/methods related to limited modeling5,8 or no modeling 9,10 without seeking to apply the theory/methods. Detsky (1985)8 described how the cost-effectiveness of a clinical trial could be calculated with effectiveness measured in terms of deaths prevented; because a more comprehensive outcome measure (such as QALYs) was not used, no complex decision model was needed, so the paper provides an example of how a minimal modeling approach might be applied. Meltzer (2001)5 focused on the development of bounding approaches such as the way in which burden of disease-type calculations and the expected value of perfect information could bound estimates of the value of information. Willan (2008)9 argued that the potential for imperfect implementation of health technologies should be accounted for, such as by calculating VOI with current implementation. Janssen and Koffijberg (2009)10 focused on the construction of VOI estimates with independent estimates of variability in benefits and costs.

### VOI Applications using Minimal Modeling

Tables 3 and 4 provide details of the applications in the published studies that applied limited modeling and no modeling approaches to VOI calculations, respectively. In total, our review of the academic literature found 18 applications of VOI analysis in which either a limited modeling (50%) or no modeling (50%) approach was adopted. In the limited modeling studies, the modeling component commonly involved the approximation of patient survival or life expectancy, for example, using (declining) exponential distributions.

Table 3 Details of applications (i=9) in VOI studies [k=7] using “limited modeling” approaches to VOI

Reference | Detsky, 1990^11^ | Forbes et al, 2002^26^ | Townsend et al., 2003^12^ ^[ex. a]^ | Townsend et al., 2003^12^ ^[ex. b]^ | Townsend et al., 2003^12^ ^[ex. c]^ | Ramsey et al., 2008^13^ | Meltzer et al., 2009^7^ | Girling et al., 2007^14^ | Stevenson et al., 2010^15^
Modeling of health outcomes [i.e. limited modeling component] | Life-years saved modeled using modified DEALE method | Life-years gained modeled using exponential distributions | - | - | - | Life-years gained (long term) modeled using DEALE method | Life-years gained modeled using pooled estimates from meta-analysis Incidence: distribution of survival curves and steady-state lifetime prevalence | Life-years gained modeled, using exponential (constant hazard) distribution, with mean survival from REMATCH [in OMM] and separate distributions for LVAD failures/successes | QALYs modeled by mapping from EPDS scores to utility values (SF-6D) and multiplying these values by appropriate time period, based on PoNDER trial data
Approach to value of information calculations | - Equation-based computations, parametric; - Sensitivity analysis, varying trial sizes | Simulation/bootstrapping, parametric | Scenario analysis, varying assumptions around trial evidence and implementation of CMSW service | Scenario analysis, varying assumptions around trials evidence and implementation of stabilization protocol | Scenario analysis, varying trial evidence and implementation of early elective surgery | Simulation/bootstrapping, parametric | Simulation/boot-strapping, parametric | - Equation-based computations, parametric; - Sensitivity analysis, varying assumptions around device costs | Simulation/bootstrapping, parametric and nonparametric
Application | Comparison of five trials in cardiovascular medicine (LRC trial, RCT-portion of CASS, and MRFIT trial) | Liposomal doxorubicin vs. topotecan as second-line treatment in patients with advanced ovarian cancer | Postnatal midwifery support service and standard current midwifery visits vs. midwifery visits alone | Prehospital intravenous fluid replacement vs. stabilization alone in adults with serious trauma | Early surgery vs. a period of ultrasound surveillance for patients aged 60–76 years with small AAAs | Lung–volume-reduction surgery (LVRS) vs. medical therapy (MT) for patients with severe emphysema | Perphenazine (first-generation antipsychotics) vs. all second-generation antipsychotics for patients with schizophrenia | Left ventricular assist devices (LVADs) implantation optimal medical management (OMM) in patients with end-stage heart failure (ESHF) | Group cognitive behavior therapy (gCBT) vs. routine primary care for women with postnatal depression
Setting | U.S. | U.K. | U.K. | U.K. | U.K. | U.S. | U.S. | U.K. | U.K.
Perspective | NOT STATED | NHS | NOT STATED | NHS | NHS | NIH / CMS | NIH | Health care provider | NHS
Data | Costs and effects of trials, health services delivery: 5 trials | - Patient survival: no difference [ITT] [PPO in sensitivity analysis], trial 30–49]; - Costs: trials 30–49^30^ | - Δ-point GHP scale of SF-36: varying assumptions; - CMSW service costs: approximations; - Implementation of service: expert opinion | - Patient mortality: varying assumptions; - Prehospital care services costs: approximations; - Development of prehospital care services and implementation of stabilization protocol: expert opinion | - Patient mortality, QoL (MOS): varying assumptions; - Costs of aortic grafting/regular observation: approximations; - Development of treatment of small AAAs and implementation of early elective surgery: expert opinion | - Patient survival (short term): NETT trial; - Costs of LVRS procedures: single center study31; - Medical costs for patient with COPD: National Medical Expenditure Survey; - Utility weights: HUI-III data from pilot study; - Trial cost: assumptions | - QoL/costs: CATIE study [Normal/Gamm a distribution]; - Prevalence, mortality: secondary analysis; - Trial costs: assumptions | - LVAD failures/successes, mean survival, utilities; treatment costs: REMATCH trial; - Device costs: assumptions; - Prior distributions for survival: elicitation from experts [uniform distributions] | - EPDS scores: RCT32; - Cost of providing gCBT, duration of comparative advantage for gCBT: RCT32 and expert opinion
Incidence [prevalence] | 15k – 5M | 3000 | UK birth rate | Number of trauma patients treated by a non-metropolitan ambulance service | 2000 | 20k | 52.6k [CATIE trial] | 15k | 120k
Time horizon | NOT STATED | 5 years | 5 years | 10 years | 5/10 years | 10 years | Lifetime / 30 years / 20 years | 10 years | 10 years
Discounting | NOT STATED | Effects and costs: 6% | Effects: 2%, costs: 6% | NOT STATED | NOT STATED | Effects and costs: 3% | Effects and costs: 3% | Effects and costs: 3.5% | NOT STATED
Cost-effectiveness results | - | ICER = £22k/life-year^§^ [Pr(CE) = 0.80]^*^ | ICER = £2-3.50/ per +1-point GHP scale of SF-36 | ICER = £3000–4330/life saved | ICER = £20k/life-year saved | ICER = $305k/QALY [Pr(CE) = 0.04] | $796k/QALY [Pr(CE) = 0.45] | NB = −£46.8k [Pr(CE) = 0.002]^*^ | ICER = £36k/QALY [Pr(CE) = 0.2]
Value of information results [per patient] | ICERs of trials = $5461-102k/life-year | EVPI ≈ £800^*^ | - | - | - | - | - | EVPI = £6^*^ | EVPI = £53.50^*^
Value of information results [per population] | - | pEVPI ≈ £10.7M^*^ | - | - | - | pEVPI = $46.0M^*^ pEVSI = $41.0M^*^ pENBS = −$19.0M, SS = 1250/arm^*^ | pEVPI = $308B pENBS = $13.8B, SS ≈ 4000–4500/arm | pEVPI = £775k^*^ | pEVPI = £64M^*^
| | ^§^ deterministic, ^*^ λ = £30k/life-year | | | | ^*^ λ = $50k/QALY | ^*^ λ = $50k/QALY | ^*^λ = £30k/QALY, device costs = £60k32 | ^*^ λ = £30k/QALY

AAAs = abdominal aortic aneurysms; λ = cost-effectiveness threshold; CASS = Coronary Artery Surgery Study; CATIE = Clinical Antipsychotic Trials of Intervention Effectiveness; CI = confidence interval; DEALE = Declining Exponential Average Life Expectancy; GHP = General Health Perception; ICER = incremental cost-effectiveness ratio; LRC = Lipid Research Clinics-Coronary Primary Prevention Trial; MRFIT = Multiple Risk Factor Intervention Trial; NB = net benefit; NETT = National Emphysema Treatment Trial;; pENBS = population expected net benefit of sampling; pENG = population expected net gain [equivalent to pENBS]; pEVPI = population expected value of information; pEVSI = (population) expected value of sample information; Pr(CE) = probability that health care technology is cost-effective; QALY = quality-adjusted life-year; SS = sample size

Table 4 Details of applications [k=9] in VOI studies [n=12] using “no modeling” approaches to VOI

Reference | Omenn, 2001^16^ | A: Willan and Pinto, 2005^17,[a]^ B: Eckermann and Willan, 2007^18^ C: Willan and Kowgier, 2008^19,[a]^ D: Eckermann and Willan, 2009^4^ E: Willan and Eckermann, 2010^20,[a]^ | A: Willan and Pinto, 2005^17,[b]^ C: Willan and Kowgier, 2008^19,[b]^ | Willan, 2007^21^ | Barton et al., 2008^22^ | Fenwick et al., 2008^23^ | Groot Koerkamp et al., 2008^24^ | Groot Koerkamp et al., 2010^25^ | Willan and Eckermann, 2010^20,[b]^
Modeling of health outcomes | Specificity and sensitivity of testing based on assumptions [see also Data] | Direct measurement of QALYs [see also Data] | Direct measurement of QALYs [see also Data] | Direct measurement of risk of cardiovascular event [see also Data] | Direct measurement of QALYs [see also Data] | Direct measurement of life-years gained [see also Data] | Conversion of EuroQol-scores into utility values using Dolan tariff | Conversion of EQ5D-scores to utilities using Dutch scoring algorithm | Direct measurement of dyspepsia symptoms [see also Data]
Approach to VOI calculations | Equation-based computations, parametric | Equation-based computations, parametric | Equation-based computations, parametric | Equation-based computations, parametric | Simulation/boot-strapping, parametric | Simulation/boots trapping, nonparametric | Simulation/boots trapping, parametric | Simulation/boots trapping, parametric and nonparametric | Equation-based computations, parametric
Application | National Toxicology Program carcinogenicity test vs. MultiCASE prediction of potential carcinogenic risk | Early (week 34) vs. late (week 37) external cephalic version (ECV) in pregnant women presenting in the breech position | Prednisone plus mitoxantrone vs. prednisone alone in patients with hormone-resistant prostate cancer | Ramipril (ACE inhibitor) vs. management strategies of placebo in patient over 55 years at risk | Comparison of seven different management strategies for GERD | Rate- vs. rhythm-control treatments for persons with atrial fibrillation | Radiography and magnetic resonance (MR) imaging vs. radiography alone in patients with acute knee trauma (in an ED setting) | Endovascular revascularization vs. supervised exercise training for patients with intermittent claudication | Omeprazole plus metronidazole/clarithromycin vs. omeprazole plus placebos in patients with dyspepsia
Setting | U.S. | A,B,C,E: North America; D: US, UK and Australia | All: Canada | U.S. and Canada | Canada | U.S. | The Netherlands (NL) / European Union (EU) | The Netherlands | Canada
Perspective | NOT STATED | All: Societal | All: Societal | Government/private donation-based or philanthropic agency | Provincial government payer | Third-party payer | Societal | Societal | Societal
Data | - Specificity, sensitivity, costs of testing: assumptions; - Social cost of false positive and false negative testing: assumptions | All: QALYs: pilot study34 no differences bet. jurisdictions [assumptions] All: Costs: no difference, no differences bet. jurisdictions [assumptions] All: Trial costs: assumptions B,E: Accrual rate; time period for data collection/analysis : assumptions C: Probability of stopping: assumptions B: Reversal cost: assumptions E: Implementation: assumptions | All: QALYs, costs: Canadian trial35, 36 All: Trial costs: assumptions C: Probability of stopping: assumptions | - Risk of cardiovascular event, costs: HOPE study; - Trial costs: assumptions | QALYs, costs: replication of previous analyses37 | Survival and cost: AFFIRM trial, patient level data | - EuroQoL-scores, (non)medical costs: RCT38; - Trial costs: assumptions | - EQ5D-scores, (non)medical costs: RCT39; - Trial cost: assumptions | - Dyspepsia symptoms, costs: Cadet Hp-trial40; - Trial costs: assumptions; - Accrual rate, time period for data collection/analysis: assumptions
Incidence [prevalence] | US population | A NOT STATED; B,E 50k; C 100k; D 50k (U.S.), 10k (U.K.), 3k (Australia) | A 10k; C 60k | NA | NA | 500k [2.3M] | 20k (NL) / 561k (EU) | 10k | 50k
Time horizon | NOT STATED | All: 20 years | All: NOT STATED | 4.5 years [HOPE study] | 1 year | 5.65 years | 10 years | 5 years | 20 years
Discounting | NA | A NOT DONE; B,C,D,E NOT STATED | A NOT DONE; C NOT STATED | Costs: 3% | NA | Effects and costs: 3% | Effects and costs: 3% | Effects and costs: 3% | NOT STATED
Cost-effectiveness results | - | - | - | - | ICERs = $7755, $12,183, $110.8k/QALY [Pr(CE) ≈ 0.33, 0.18, 0.45 ] | ICER = $4.98M/life-year gained [Pr(CE) = 0.51] | NB = €2467 [95% CI = €515, €4419]^*^ | NB = €2170 [95% CI = €-2818, €6685] | -
Value of information results [per patient] | - | - | - | Threshold number of patients benefiting from technology = 4.8M (U.S.); 2.28M (Canada)^*^ | EVPI ≈ $14^*^ | | EVPI = €2.1^*^ | | -
Value of information results [per population] | pEVPI = $62,0M | A. pENG = $0.7M, SS = 346/arm^*^; B. pENG = $0.4M, SS = 284/arm^*,§^; C. pENG = $1,4M, SS = 155/arm (stage 1), 124/arm (stage 2)^*^; D. Global pENG = 0, global SS = 0/arm (U.S.), 0, 0/arm (U.K.), $0.9M, 339/arm (Australia); E. pENG = 38.2M, SS = 489/arm^*,†^ | A pENG = $0, SS = 0/arm; C pENG = $1.6M, SS = 66/arm (stage 1), 163/arm (stage 2)^*^ | - | - | pEVPI: $23M^*^ | - pEVPI: €365k (NL) / €10.2M (EU)^*^; - pENBS = NA (NL) / €3,8M, SS = 2500/arm (EU)^*^ | - pEVPI = €11.0M^*^; - pENBS = €7.3M, SS = 475/arm^*^ | pENG = $8.0M, SS = 109/arm ^*^
| | ^*^ λ = $1000/non-caesaran delivery (U.S. and U.K.); $750 (Australia) ^§^ Reversal cost = $ 2.0 M ^†^ γ = 0.67, β = 2.33 | ^*^ λ ≈ $20k/QALY | ^*^ λ = $10k/cardiovascular event saved | ^*^ λ = $50k per QALY | ^*^ λ = $50k/life-year | ^*^ λ = €80k/QALY | ^*^ λ = €80k/QALY | ^*^λ = $1,000/year without/minimal dyspepsia symptoms, γ: 0.67, β = 2.33

λ = cost-effectiveness threshold; AFFIRM = Atrial Fibrillation Follow-up Investigation of Rhythm Management; CI = confidence interval; ICER = incremental cost-effectiveness ratio; NA: not applicable; NB = net benefit; pENBS = population expected net benefit of sampling; pENG: population expected net gain, equivalent to (p)ENBS; pEVPI = population expected value of information; pEVSI = population expected value of sample information; Pr(CE) = probability that health care technology is cost-effective; QALY = quality-adjusted life-year; SS = sample size

The majority of the minimal modeling studies involved pharmaceuticals or other clinical interventions, including surgical procedures12,13,25 and medical devices.14 Six VOI studies were conducted in the U.K., five in the United States, three in Canada, and two in The Netherlands, while four occurred across different jurisdictions (e.g., North America or the European Union). Five out of 18 VOI applications were undertaken from a societal perspective, as one would expect given the public characteristics of evidence collection.

As shown in Table 3, 7 of the 18 VOI applications were based on equation-based computations relying on parametric assumptions for the costs and effects of the health technologies under evaluation. This included two early studies by Detsky (1990)11 and Omenn (2001)16, and five recent and related studies by Willan and colleagues.9,17,19–21 Four studies, three by Townsend and colleagues12^[a,b,c]^ and the Detsky (1990)11 study, adopted an alternative approach to minimal modeling in that the incremental cost-effectiveness ratios of future trials or evidence to be developed were calculated on the basis of prior information or elicitation of expert opinion of the cost and effects of the health technologies and costs of research. All the remaining eight VOI applications, reflecting the vast majority of the more recent studies, used simulation/bootstrapping of raw data on costs and effects (QALYs). Parametric simulation/bootstrapping techniques (in R, Microsoft Excel, or Stata) were often used to explore decision uncertainty and establish VOI measures in these studies.

Most VOI application studies reported outcomes in terms of person level estimates of the value of information (e.g., EVPI ). Population-level estimates of the value of information (e.g., pEVPI) were reported less commonly, despite that these measures establish the necessary and sufficient condition for decisionmaking about research funding. EVPI results varied from €2.1 ($2.89) to £1064 ($1675) per patient, while the population values for pEVPI ranged between €365,000 ($504,649) and $308 billion.^*^ Where separate measures of benefits and costs were available, the value of partial information on benefits and costs was calculated in some cases.

## Comparison of VOI Calculations Using Minimal Modeling

Perhaps not surprisingly, given that the minimal modeling approach to VOI is driven primarily by empirical concerns, most of the papers we found that discussed approaches we would classify as discussing minimal modeling approaches to VOI were empirical applications. Aside from the fact that the results of VOI studies vary with the uncertainty in the costs and effects of the health technologies under evaluation, the results of such analyses are often difficult to compare due to variation in the perspective and time horizon for the analysis, the size of population targeted and the actual use or implementation of health technologies in the specific settings. Moreover, difference may exist in the approach to decision analysis (e.g., nonparametric bootstrapping vs. parametric equation-based computations), the use of end outcomes (e.g., clinical events avoided vs. QALYs), and the threshold value for cost-effectiveness in the jurisdictions in which the VOI analysis is applied.

Some of these differences in study assumptions (such as discount rates and assumptions about the value of a QALY) almost certainly cannot even approximately be adjusted for based on the published results, which makes it nearly impossible to compare value of research calculations across studies. However, some differences across studies, such as the population studies (e.g., U.K. vs. U.S.), time horizon (e.g., 5 or 10 years), currency (e.g., $, £, €), and year can be fairly readily adjusted for. To demonstrate this, we attempted to compare results across minimal modeling studies (i.e., limited modeling and no modeling studies) for all studies possible. Populations from the different studies were normalized to reflect the U.S. population, with a horizon of 10 years and denominated in 2010 U.S. dollars using historical currency exchange rates and the general U.S. Consumer Price Index.

As shown in Tables 5 and 6, standardizing on these factors often had large effects on the value of research, suggesting the importance of developing approaches to standardize population level VOI analyses if they are to be compared to each other. Estimates of the standardized VOI varied from around $2 million to nearly $125 billion, with most studies distributed broadly across the range from $2 million to $600 million. The $125 billion study, analyzing uncertainty in the value of atypical antipsychotics in schizophrenia, reflects to large degree the fact that schizophrenia affects 1 percent of the population throughout their entire life, and the substantial uncertainty about the effects of these medications on both quality of life and costs.

Table 5 Comparison of VOI estimates across limited modeling studies

Reference | Detsky, 1990 | Forbes et al, 2002 | Townsend et al., 2003 [a] | Townsend et al., 2003 [b] | Townsend et al., 2003 [b] | Ramsey et al., 2008 | Meltzer et al., 2009 | Girling et al., 2007 | Stevenson et al., 2010
Year of study | - | 2000 | - | - | - | 1996 | 2002 | 2007 | 2008
Country | - | U.K. | - | - | - | U.S. | U.S. | U.K. | U.K.
Per Patient VOI | - | £800.00 | - | - | - | - | - | £6.00 | £53.50
Population VOI in Millions | ICER-Trial | £11 | ICER-Trial | ICER-Trial | ICER-Trial | $46 | $308,000 | £1 | $64
Applied scale factor for population at risk * | - | 5.01 | - | - | - | 1.00 | 1.00 | 5.01 | 5.01
Applied scale factor for time horizon | - | 2.00 | - | - | - | 1.00 | 0.33 | 1.00 | 1.00
Applied (historical) currency exchange rate † | - | 1.52 | - | - | - | 1.00 | 1.00 | 2.00 | 1.86
Consumer price index factor ‡ | - | 1.27 | - | - | - | 1.39 | 1.21 | 1.05 | 1.01
Calculated standardized pEVPI (in $1,000,000) | NA | $206 | NA | NA | NA | $64 | $124,658 | $8 | $603

SS = sample size; ICER-T = incremental cost-effectiveness ratio of trial; pEVPI = population expected value of information; pENG = population expected net gain to conducting trial; EVSI = expected value of sampling

* 2010 estimates by the Population Division of the United Nations Department of Economic and Social Affairs, http://en.wikipedia.org/wiki/List_of_countries_by_population

† OANDA, http://www.oanda.com/currency/historical-rates, average daily over period 01/01/year of study and 12/31/year of study

‡ US Department of Labor, Bureau of Labor Statistics, CPI Inflation Calculator, http://www.bls.gov/data/inflation_calculator.htm

Table 6 Comparison of VOI stimates across no modeling studies

Reference | Omenn, 2001 | [A: Willan and Pinto, 2005 [1]]; [B: Eckermann and Willan, 2007]; [C: Willan and Kowgier, 2008 [CT] [1]]; [D: Eckermann and Willan, 2009]; [E: Willan and Eckermann, 2010] | [E: Willan and Pinto, 2005 [2]]; [F: Willan and Kowgier, 2008 [CT] [2]] | Willan 2007 [CT] | Barton et al., 2008 | Fenwick et al., 2008 | Groot Koerkamp et al., 2008 | Groot Koerkamp et al., 2010 | Willan and Eckermann, 2010
Year of study | 2001 | - | - | - | 2000 | 2002 | 2000 | 2005 | -
Country | U.S. | - | - | - | U.S. | U.S. | The Netherlands | The Netherlands | -
Per Patient VOI | - | - | - | EVSI/ENG | $14 | - | € 2.10 | - | -
Population VOI in Millions | $62 | pENG, SS | pENG, SS | - | - | $23 | € 0.37 | € 11 | pENG, SS
Applied scale factor for population at risk * | 1.0 | - | - | - | 13975^§^ | 1 | 19 | 19 | -
Applied scale factor for time horizon | 1 | - | - | - | 10 | 1.77 | 1 | 2 | -
Applied (historical) currency exchange rate † | 1.00 | - | - | - | 1.00 | 1.00 | 0.92 | 1.25 | -
Consumer price index factor ‡ | 1.23 | - | - | - | 1.27 | 1.21 | 1.27 | 1.12 | -
Calculated standardized pEVPI (in $1,000,000) | $76 | NA | NA | NA | $2 | $49 | $8 | $573 | NA

SS = sample size; ICER-T = incremental cost-effectiveness ratio of trial; pEVPI = population expected value of information; pENG = population expected net gain to conducting trial; EVSI = expected value of sampling

* 2010 estimates by the Population Division of the United Nations Department of Economic and Social Affairs, http://en.wikipedia.org/wiki/List_of_countries_by_population

† OANDA, http://www.oanda.com/currency/historical-rates, average daily over period 01/01/year of study and 12/31/year of study

‡ U.S. Department of Labor, Bureau of Labor Statistics, CPI Inflation Calculator, http://www.bls.gov/data/inflation_calculator.htm

§ http://books.google.com/books?id=WSP6wdD_8MEC&pg=PA21&lpg=PA21&dq=incidence+GERD+usa&source=bl&ots=wK3IeR74Vv&sig=URVMDq1Dt-xW63bB5qiM4nNKN9k&hl=en&ei=QzTGTJP4LM3Angenh_2nAQ&sa=X&oi=book_result&ct=result&resnum=1&ved=0CBUQ6AEwADgU#v=onepage&q=incidence%20GERD%20usa&f=false

* Foreign currencies converted to $US using October 2010 exchange rates.