# Introduction

Biomedical research, including clinical research, is believed to have very large returns.1 However, funds for this research are limited relative to the vast number of research questions that could be studied. This makes decisions about how to allocate clinical research spending especially important. For example, systematic reviews of clinical topics, such as those performed by the United States (U.S.) Agency for Healthcare Research and Quality’s (AHRQ) Evidence-based Practice Centers (http://www.ahrq.gov/clinic/epc/), often identify many research gaps, and decisions need to be made about how to prioritize those research gaps, within and across clinical topics. Techniques to prospectively estimate of the value of research could potentially improve the outcomes of research spending. However, predicting the value of research is difficult because the outcomes of research are inherently uncertain and the value of those uncertain outcomes may be difficult to characterize.

Value of information (VOI) analysis provides a coherent theoretical framework for estimating the expected benefits from clinical research studies. These estimates can aid in the design and prioritization of those studies. Performing VOI analysis requires mechanisms to characterize the uncertainty of the effects of interventions being studied on outcomes. This involves both determining which of the options being considered is preferred for all the possible outcomes of the study, and determining what the value of that preferred option is as compared to the alternatives. Most VOI studies use decision analytic models to characterize this uncertainty. However, the complexity of constructing such models makes VOI difficult to apply and limits its implementation.

Clinical studies that directly characterize uncertainty in comprehensive measures of health outcomes (e.g., both quality-adjusted life-years [QALYs] and costs) make it possible to perform VOI analysis with only minimal modeling, which we define as VOI that is performed without full disease and/or decision analytic modeling. To accomplish this, uncertainty in patient-level outcomes for VOI can be bootstrapped from the results of clinical trials that report a comprehensive outcome measure, which we define as a measure sufficient to conclude whether one outcome for a patient is better or worse than another outcome. A clinical trial that directly measures the effect of an intervention on quality-adjusted life expectancy is the most obvious example of this, but studies of interventions that have their main effects in terms of quality of life are still potentially amenable to minimal modeling by constructing only a simple model of survival (perhaps based on standard life tables). In practice, the minimal modeling approach is most likely to be applicable to interventions for which effects on survival or quality of life occur quickly enough to be measured directly in a clinical trial.

The purpose of this paper is to define and demonstrate a “minimal modeling approach” to VOI that can be used to prioritize research. We begin by outlining a theoretical framework for estimating the expected population value of information from conducting research, which we then use to define and categorize existing approaches to VOI as either “full modeling” or “minimal modeling.” We further distinguish two subtypes of minimal modeling approaches to VOI: “limited modeling,” and “no modeling,” which we define and discuss in detail in the Theoretical Framework chapter. We review existing VOI studies in the Literature Review chapter, focusing on those that describe and apply minimal modeling approaches. In the Applications chapter, we illustrate and discuss the application of minimal modeling VOI methods to two new clinical applications: (1) the use of azithromycin versus amoxicillin/clavulanate in the treatment of acute bacterial sinusitis; and (2) the use of erlotinib plus gemcitabine versus gemcitabine alone in the treatment of pancreatic cancer. These applications were selected because published results from clinical trials were available that provided preliminary estimates of the uncertainty in comprehensive outcomes as defined above.

Our results confirm that minimal approaches to VOI can be readily applied to estimate the expected benefits of research in instances where data on comprehensive measures of outcomes are available. These results suggest that minimal modeling can offer an advantage over traditional VOI analysis when rapid or low-cost estimates of the value of research are needed. They also suggest that minimal modeling approaches can be a useful complement to adaptive clinical trial design because the data collected at each stage of an adaptive trial can serve as a basis for minimal modeling to inform subsequent stages of the trial.2