# Conclusions

While the use of decision-analytic models to calculate the expected value of information is the dominant approach to the development of VOI methods to inform research priorities, minimal modeling approaches based on information on comprehensive health outcome measures can provide a less-demanding approach to performing VOI analysis. Our review of published VOI studies identified 17 applications of minimal modeling approaches in the academic literature and one in the grey literature. In addition, we performed two new minimal modeling VOI analyses. These two new minimal modeling VOI analyses each took only a day or two of work, as opposed to what we expect would be months for a typical full modeling approach to VOI.

Our results show that minimal modeling approaches can be readily applied in some circumstances and can provide evidence of vast variation in the value of research for different studies that can range from as little as $2 million to as much as $125 billion, a nearly 100,000-fold difference in value. The immense range of these estimates suggests that VOI analysis can provide insights into the value of research that may provide information that challenges and extends intuitive approaches to informing priorities for research. Our results also show that, as with full-modeling approaches to VOI, minimal modeling approaches demonstrate that VOI depends on the criteria used to define a decision, with very low VOI estimates if the gemcitabine decision is made only on the basis of health benefits, and much larger VOI if the decision is to be made also considering costs.

Our review and new analyses suggest several general situations in which minimal modeling approaches may be readily applicable. One of these approaches is when an intervention affects quality of life alone so that effects on survival do not need to be modeled (e.g., Meltzer [2009]7). Another is when a study follows cohorts of patients randomized to the time of treatment from the time of treatment to death, recording all relevant outcomes (perhaps survival, quality of life, and costs at all points in time until death, ideally combined into net health benefit). Third, a study might collect comprehensive outcomes data from a trial in which survival is similar between two arms after some point, but survival or quality of life up to that point might differ. How often these criteria are met when considering specific research gaps is an empirical question, but it is clear that the data requirements will not be met in some circumstances so that minimal modeling approaches cannot fully substitute for full-modeling approaches to VOI.

Where the data needed for minimal modeling approaches to VOI is available, we found that simulation methods that use bootstrapping to address value of information have been most commonly used in the literature recently. To simplify such calculations for others, we have written a Stata command—evpi—that can be used to calculate expected value of information for conducting comparative effectiveness research for two treatments. One must specify as input a dataset that contains the empirical distribution of mean costs or effectiveness or both for each treatment. The command allows specification of the decisionmaking criteria (based on costs, effects, or cost-effectiveness), incidence, prevalence, time horizon of technology, discount rate, and the range of threshold values for willingness to pay for an effectiveness outcome. It provides options to draw both an acceptability curve and an expected VOI curve, as illustrated in Figures 2 and 3. The EVPI software is available from the authors on request, although we should note that development of this software is ongoing to extend its capability to include comparison of multiple treatments.

In addition to the significant data requirements of the approach we discuss, additional limitations of the minimal modeling framework should be noted. First, the above limitations imply that it will generally be impossible to apply the minimal modeling approach to VOI to study the value of research in interventions for chronic disease, since studies rarely follow outcomes fully to their final outcome. Full modeling approaches to VOI are likely more appropriate in those settings because of the tendency to rely on intermediate outcomes in clinical trials in chronic disease. Also, even when long-term trials are performed that measure comprehensive outcomes, their length and costs make the potential benefits of minimal modeling approaches in terms of speed and cost less important.

Second, the absence of a decision model makes it impossible to calculate the expected value of perfect partial information on specific parameters that may be partial determinants of the outcomes of the interventions being considered. One exception to this may be the separate effects of costs and outcomes. Not using decision models also means that the results of a VOI analysis cannot be tailored to a somewhat different clinical situation by the manipulation of the parameters of the model. Finally, the minimal modeling approach is limited by the fact that many cutting-edge areas of medical technology may have not prior data with which to inform a minimal modeling approach. Cases such as these may require the use of full modeling approaches to develop meaningful estimates of the value of research.

Nevertheless, when the minimal modeling approach is feasible, its advantages are potentially important in allowing VOI analyses to be done in situations where the cost of doing a study would be too small to justify spending significant spending on a VOI analysis. One example of this would be where the study considered might be the performance of a systematic review. Similarly, a minimal modeling approach might be useful when a full modeling approach might have certain advantages but the expertise to perform a full modeling approach simply is not available. Other examples might be when the results of a VOI analysis were required very quickly, such as when a decision must be made about funding a clinical trial or continuing one already in progress. The latter case also reinforces the argument made above that minimal modeling VOI may be of use in the context of adaptive clinical trials, because the data collected at each stage of an adaptive trial can provide data for a minimal modeling approach that can be rapidly used to inform subsequent stages of the trial. Indeed, in cases of new technologies where no prior data is available, appreciation of the minimal modeling approach may provide rationale for an initial small and underpowered trial as the first step in a potentially larger adaptive trial, with later design decisions specified based on the results of the subsequent VOI analyses.

Finally, it should be noted that resources invested in value of information analysis could, at least hypothetically, also be invested in directly seeking to answer clinical research questions rather than choosing which clinical research questions to answer. This is a real tradeoff; it is surely possible that investments in VOI might have lower returns than investments in other types of research. However, the range of value of research estimates we report above—from as little as $2 million to as much as $125 billion—suggests that when a minimal modeling approach to VOI can be applied, the several days of work involved seem likely to be well spent if they even rarely cause changes in research priorities that are for the better.