# Applications

To assess the potential of minimal modeling approaches to provide information on the prospective value of research, we discuss two new clinical applications that do not require survival modeling. In the first application, we study azithromycin versus amoxicillin/clavulanate in acute bacterial sinusitis. We chose this application as an example where the outcome is something other than mortality, and because the treatments differ only in the rate at which symptoms resolve and in their costs. In the second application, we study erlotinib and gemcitabine versus gemcitabine alone in pancreatic cancer. This application was chosen because we were able to find published clinical trials that follow patients to an endpoint of death. Appendix A provides details of both applications.

## Application 1: No survival modeling with no survival effects—the case of azithromycin versus amoxicillin and clavulanate in acute bacterial sinusitis

### Background and Setting

In the United States, approximately 1 billion cases of acute rhinosinusitis and 20 million cases of acute bacterial rhinosinusitis are diagnosed every year. About 50 percent of people with clinically diagnosed acute sinusitis have a bacterial sinus infection. Antibiotics are the primary treatment for such infections, and they help in early resolution of symptoms. A recent comparative effectiveness study compared a single 2-gram dose of azithromycin extended release to 10 days of amoxicillin/clavulanate (875 mg/125 mg) twice daily. The primary outcome was resolution of symptoms within 5 days.41 At day 5, 70/236 patients (29.7%) in the azithromycin extended-release arm and 45/238 patients (18.9%) in the amoxicillin/clavulanate arm had resolution of symptoms (difference: 10.8%; 95% confidence interval [CI]: 3.1–18.4%). By day 28, 26/236 patients (11.0%) in the azithromycin extended release arm and 27/238 patients (11.3%) in the amoxicillin/clavulanate arm had used additional antibiotics (difference: −0.4%; 95% CI: −6.1% to 5.3%). Additional physician visits, quality of life, and overall satisfaction were similar between groups. Since the single dose of azithromycin is more expensive than the course of amoxicillin/clavulanate, the superior outcomes with azithromycin raise questions also of cost-effectiveness.

### Aims

We sought to determine what the expected value of additional studies would be to verify the superiority of azithromycin in terms of (1) days to symptom resolution, and (2) the net benefit of azithromycin, where the extra costs of treatment are subtracted from the benefits (denominated in monetary units).

### Modeling of Health Outcomes, Approach to VOI Calculations, and Data

We used a no-modeling approach to VOI. First, we used published data on time to symptom resolution presented in the form of survival curves to recover the individual level data for time to symptom resolution under the two treatment arms. As a validation of this exercise, we were able to closely replicate the published data on the survival curves, the hazard ratio, and its significance using our individual level data. These are presented in Appendix B. Mean time to symptom resolution within 14 days of treatment initiation for each treatment was obtained by averaging the time to symptom relief over patients in each arm. One thousand bootstrap replicates of the individual-level data provided the distribution of the mean time to symptom relief under each arm. This distribution is shown in Appendix B.

To calculate net benefit, we accounted for both uncertainty in time to symptom resolution and willingness to pay (WTP) and subtracted costs of treatment from their product. Using average wholesale prices reported in the Red Book, 10 days of oral amoxicillin/clavulanate potassium 875 mg/125 mg every 12 hours was found to be $31.99 (2010 prices) while a single oral dose of azithromycin extended release (2 g) was found to be $55.68.^42^ The mean WTP was $73.2 (Standard Error [SE]=6.66) in 2010 U.S. dollars.

We estimated the individual level value of perfect information by bootstrap sampling out of the distribution of average benefits and costs and averaging the net benefit of azithromycin over amoxicillin/clavulanate whenever azithromycin had a positive net benefit.

### Perspective, Incidence, Time Horizon, and Discounting

Our population EVPI calculations were based on an annual incidence of 10 million cases of infected acute sinusitis. We arbitrarily chose a 10 -year horizon for our analysis assuming that a superior treatment would become available by that time. A 10-year horizon also sits approximately between the expiration dates Pfizer has for extended-release azithromycin in the tablet (U.S. Patent 6,068,859, exp. 5/30/2017) and suspension forms (U.S. Patent 6,984,403, exp. 2/14/2024). We used a discount rate of 3 percent.

### Cost-Effectiveness Results and Decisions Based on Current Information

Patients receiving azithromycin extended release had a mean time to resolution of 7.55 days (SE=0.260) compared to 8.12 days (SE=0.210) for patients receiving amoxicillin/clavulanate (p value for difference 0.077). Based on currently available information on time to symptom resolution only, the treatment decision should be the use of azithromycin extended release. The net benefit of treatments is calculated based on valuing faster time to resolution using a published estimate of mean WTP for preventing a day of sinus congestion collected through a population-based survey.43 Based on expected net benefit criteria, current treatment decision would still be azithromycin extended release (= [8.12 – 7.55] * $73.20 – [$55.68 – $31.99] = $18.20).

### VOI Results

When we based our treatment choice decisions on duration of symptoms only, the baseline population value of perfect information was about $40 million and ranged from $13 million to $109 million over a wide range of threshold WTP values ($25 to $200 per day of avoided sinus congestion). This is driven by the fact that the chance that future information may change our current decision of using azithromycin extended release based on effectiveness results was only about 4 percent.

When costs of treatments were also considered for choosing between treatments, the value of future research on effectiveness maximized at around a threshold value of $50/day of avoided symptoms and amounted to $400 million. This was the threshold where the probability of current decision that azithromycin extended release was cost-effective reached 50 percent. Figure 2 presents the acceptability curve and the EVPI curve over a range of threshold WTP values. At the baseline threshold of $73, the expected value of future research was $250 million.

Figure 2 Acceptability curve and population expected value of perfect information (EVPI) curve for comparing azithromycin extended release versus amoxicillin/clavulanate in the treatment of acute sinusitis

Figure 2 displays adjacent graphs of the acceptability curve and the population expected value of perfect information (EVPI) curves for comparing azithromycin extended release versus amoxicillin/clavulanate in the treatment of acute sinusitis over a range of threshold willingness-to-pay (WTP) values. The graph on the left side displays the acceptability curve, and the graph on the right side displays 3 curves. The first is the EVPI curve for both cost and effectiveness, the second is the partial EVPI curve for just effectiveness, and the third is the partial EVPI curve for just costs. This figure is described further in the “VOI Results” section for the first application as follows: “When we based our treatment choice decisions on duration of symptoms only, the baseline population value of perfect information was about $40 million and ranged from $13 million to $109 million over a wide range of threshold WTP values ($25 to $200 per day of avoided sinus congestion). This is driven by the fact that the chance that future information may change our current decision of using azithromycin extended release based on effectiveness results was only about 4%. When costs of treatments were also considered for choosing between treatments, the value of future research on effectiveness maximized at around a threshold value of $50/day of avoided symptoms and amounted to $400 million. This was the threshold where the probability of current decision that azithromycin extended release was cost-effective reached 50 percent. Figure 2 presents the acceptability curve and the EVPI curve over a range of threshold WTP values. At the baseline threshold of $73, the expected value of future research was $250 million.”

### Conclusions

If treatment costs are not considered, the value of future research that can generate more precise estimates results on comparative time to symptom relief between azithromycin extended release versus amoxicillin/clavulanate in the treatment of acute sinusitis is low at any reasonable threshold value of cost per day of avoided symptom. This is because additional research is very unlikely to reverse the current conclusion that azithromycin provides more rapid resolution of symptoms. However, when treatment costs are considered, there is a substantial probability that azithromycin extended release is not cost-effective at current prices and that research to better clarify the most cost-effective treatment would be highly valuable. In addition, because the results used for this analysis come from a single study, an argument could be made additional studies even of outcomes if one believed that the results of this study might not be generalizable to other settings. For example, reasons for desiring additional studies besides the one used for this VOI analysis could include incomplete followup in the intervention and control groups (both 68–69%) that require a per-protocol rather than intention-to-treat analysis, the possibility that the epidemiology of sinusitis could differ in other settings.

## Application 2: No survival modeling with survival effects from a randomized, controlled trial—the case of erlotinib and gemcitabine versus gemcitabine in pancreatic cancer

### Background and Setting

Pancreatic cancer is the fourth most common cause of cancer death in the United States, with an estimated 38,000 new cases annually.44 More than 90 percent of patients develop metastasis, and survival averages only 2 to 4 months in the absence of treatment.45 Since 1997, gemcitabine has been the primary treatment for patients with metastatic pancreatic cancer. Recently, a Phase III trial documented a statistically significant improvement in survival with a combination of gemcitabine plus erlotinib compared to gemcitabine alone.46

### Aims

We sought to assess the value of more precise information on the comparative effectiveness and cost-effectiveness of gemcitabine plus erlotinib compared to gemcitabine alone in patients with metastatic pancreatic cancer. These values will only be positive if future information can change treatment decisions. In this empirical analysis, we assume that current treatment choices are based on either current information on effectiveness (i.e., survival) or cost-effectiveness.

### Modeling of Health Outcomes, Approach to VOI Calculations, and Data

We used the published overall survival curves from the Phase III study to recover the individual level survival data under the two treatment arms. As a validation of this exercise, we were able to closely replicate the published data on the survival curve, the hazard ratio, and its significance using our individual level data. These are presented in Appendix C. Since almost all of the patients were followed until their death so that there was no difference in survival at the end of the study period, mean survival under each treatment was obtained by averaging the duration of survival over patients in each arm. One thousand bootstrap replicates of the individual-level data were used to generate the distribution of the mean survival under each arm. This distribution is shown in Appendix C. We emphasize that the approach to modeling survival here was directly based on the data from the clinical trial as opposed to modeling the progression of disease through health states and probability of death given health state as is typically done when a decision analysis model is used to model survival in a full-modeling approach to VOI.

A challenge in our analysis was the lack of information on variability in costs. To estimate EVPI for costs and effectiveness, we assumed a cost distribution in which the variance of the individual level costs under each treatment was proportional to the square of its mean. We used alternate distribution for costs (here we present results based on gamma distribution, but alternate results under a normal distribution were similar) maintaining this mean variance relationship. We estimated a distribution of mean costs arising out of a sample size similar to that of the Phase III trial.

### Perspective, Incidence, Time Horizon, and Discounting

Our EVPI calculations were based on a prevalence of 35,000 patients and an annual incidence of 25,000 patients over a 5-year horizon, with incidence calculated based on an age-adjusted incidence rate of 11.7 per 100,000, an adult U.S. population of 75 percent if 310,000 and 92 percent of patients with pancreatic cancer presenting with advanced cancer. 47 We used a discount rate of 3 percent.

### Cost-Effectiveness Results and Decisions Based on Current Information

Patients receiving gemcitabine plus erlotinib had a mean life expectancy of 0.69 years (SE=0.027) compared to 0.610 years (SE=0.026) for patients receiving gemcitabine alone. Based on information on effectiveness only, the current treatment decision that maximizes life expectancy is gemcitabine plus erlotinib. The annual cost (2010 U.S. dollars) of gemcitabine plus erlotinib therapy was estimated to be $29,238 while for gemcitabine alone was estimated to be $15,702.^48^ Based on cost-effectiveness, current treatment decision should be the gemcitabine plus erlotinib only if the maximal threshold WTP for a year of life is above $180,000. Below that threshold, gemcitabine alone is the cost-effective treatment of choice.

### VOI Results

When we based our treatment choice decisions on effectiveness only, the population value of perfect information was close to zero (<$10 million) over a wide range of threshold WTP values ($5K/Life year to $200K/Life year). This is because the chance that future information may change our current decision of using gemcitabine plus erlotinib based on effectiveness results was less than 3 percent.

Figure 3 presents the acceptability curve and the EVPI curve over a range of threshold WTP values. As expected, at a WTP of $180,000 per QALY the probability that gemcitabine plus erlotinib is cost-effective compared to gemcitabine alone is 50 percent. This is also the WTP where the value of future research on more precise estimation of the comparative cost-effectiveness is maximized at about $400 million. When the WTP per QALY drops to $100,000 per QALY, the value of additional research is less than $20 million. Note that in this example, when treatment decisions are made based on cost-effectiveness, all of the future value of research is driven by the value of acquiring more precise information on effectiveness; information collected about costs could also have value and could change the value of additional information about effectiveness.

Figure 3 Acceptability curve and population expected value of perfect information (EVPI) curve for comparing gemcitabine plus erlotinib versus gemcitabine alone in the treatment of patients with metastatic pancreatic cancer

Figure 3 displays adjacent graphs of the acceptability curve and the population expected value of perfect information (EVPI) curves for comparing gemcitabine plus erlotinib versus gemcitabine alone in treatment patients with metastatic pancreatic cancer. The graph on the left side displays the acceptability curve, and the graph on the right side displays 3 curves. The first is the EVPI curve for both cost and effectiveness, the second is the partial EVPI curve for just effectiveness, and the third is the partial EVPI curve for just costs. This figure is described further in the “VOI Results” section for the second application as follows: “Figure 3 presents the acceptability curve and the EVPI curve over a range of threshold WTP values. As expected, at a WTP of $180,000 per QALY the probability that gemcitabine plus erlotinib is cost-effective compared to gemcitabine alone is 50 percent. This is also the WTP where the value of future research on more precise estimation of the comparative cost-effectiveness is maximized at about $400 million. When the WTP per QALY drops to $100,000 per QALY, the value of additional research is less than $20 million. Note that in this example, when treatment decisions are made based on cost-effectiveness, all of the future value of research is driven by the value of acquiring more precise information on effectiveness; information collected about costs could also have value and could change the value of additional information about effectiveness.”

### Conclusions

The value of future research that can generate more precise estimates results on comparative survival or costs between gemcitabine plus erlotinib versus gemcitabine alone in metastatic pancreatic cancer is low at any reasonable threshold value of cost per life year. This is because additional research is unlikely to change the current treatment decision recommended based on life expectancy. However, if the best treatment decision is based on cost-effectiveness, erlotinib plus gemcitabine is not cost-effective at WTP below $180,000 per QALY and gemcitabine alone is the preferred treatment. In this case, if the WTP threshold is sufficiently high, additional research on effectiveness could have an expected value as high as $400 million if the WTP per QALY is $180,000. However, if WTP is less than $100,000 per QALY, the value of research is less than $20 million, which may be too small compared to the cost of an additional clinical trial to justify the cost.