# Appendix A Details of Application 1 and Application 2

Table A1 Details of application 1 (azithromycin vs. amoxicillin/clavulanate in acute bacterial sinusitis) and application 2 (erlotinib and gemcitabine vs. gemcitabine alone in pancreatic cancer)

Application | Application 1: Azithromycin vs. Amoxicillin/Clavulanate in Acute Bacterial Sinusitis | Application 2: Erlotinib and Gemcitabine vs. Gemcitabine Alone in Pancreatic Cancer
Modeling of health outcomes (i.e. limited modeling component) | No modeling, manual replication of curve for symptom relief | No modeling, manual replication of survival curve
Approach to value of information calculations | Bootstrapping/simulation, nonparametric | Bootstrapping/simulation, nonparametric
Application | Azithromycin vs. amoxicillin/clavulanate in patients with acute bacterial sinusitis | Erlotinib and gemcitabine vs. gemcitabine in patients with pancreatic cancer
Setting | U.S. | U.S.
Perspective | Third-party payer | Third-party payer
Data | - Symptom resolution: Comparative effectiveness study [41); - Drug price: Drug Topics Red Book (42) | - Survival curves: Phase III trial (46); - Costs: assumptions
Incidence [prevalence] | 10M | 25k [35k]
Time horizon | 10 years | 5 year
Discounting | 3% | 3%
(Cost-)effectiveness results | - Effectiveness = −0.57 days to symptom resolution; - NB: $18.2 | - Effectiveness = +0.08 life-years; - ICER~$180,000/life-year
Value of information results | Effects only: pEVPI = $40M Both cost and effects: pEVPI =$250M | Effects only: pEVPI = $0 Both cost and effects: pEVPI = $400M
Willingness-to-pay | WTP = $73.20/day to symptom resolution | WTP = $180k/life-year

NB = net benefit; pEVPI = population expected value of information; WTP = willingness-to-pay

Brief description of the methods use to develop the survival curves in the two examples: After enlarging a hard copy of the published survival figure, we drew a rectangular grid of lines on the figure in order to read the treatment-specific survival fraction corresponding to each unit increment of time (a day for the sinusitis example [Appendix B] and a half-month for the pancreatic cancer example [Appendix C]). We then took an empty dataset with n observations, n corresponding to the treatment-specific sample sizes of the respective study, and assigned a time of event to each observation (representing one patient) based on the survival fraction and the corresponding time, thereby generating an individual level outcomes dataset. We validated this approach by replicating the point estimate of the hazard ratio reported in the original analysis using our generated individual-level data. We also performed a nonparametric bootstrap of the individual level data to replicate the 95 percent confidence interval of the hazard ratio reported in the original analyses. These results are presented in Appendix B and Appendix C. These bootstrap results also produced the distribution of comparative effects that we use for the value of information analyses.