# Modeling and VOI as Priority-Setting Methods: Literature Review

## Methods

### Search Strategy

We performed two PubMed^®^ searches to identify published studies relevant to this review; details of the search strategy and results of our search and screening process are provided in Appendix A.

In addition to citations identified using these searches of PubMed, a small number of additional relevant citations were identified through manual searching.

### Study Selection

We developed criteria for inclusion and exclusion based on the focus and aims of the report in investigating methods for setting research priorities. The criteria used to screen citations for inclusion and exclusion at the title-and-abstract level were as follows:

- Include articles that describe an explicit priority-setting process or provide explicit discussion or examples of VOI analyses.
- Exclude articles focused on establishing priorities for providing health services rather than prioritization of research.
- Exclude non-English articles.
- Exclude articles published prior to 1990.

We retrieved the full text of all potentially relevant literature included at the title-and-abstract screening stage for additional screening. We then conducted a second review for inclusion and exclusion. Criteria applied at this full-text stage were as follows:

- Publication must include research prioritization (excludes health services prioritization or prioritization of other topics).
- Publication must include a formal framework or process for research prioritization (excludes editorials and review articles).
- Publication must include specific research prioritization recommendations, and not only a description of a framework/process.

### Data Abstraction

We developed a data abstraction form/evidence table template for abstracting data from all included studies (Appendix B). Abstractors worked in pairs: the first abstracted the data, and the second over-read the article and the accompanying abstraction form to check for accuracy and completeness. Disagreements between abstractors and over-readers were resolved by consensus or by assistance from a third, arbitrating member of the study team.

## Results

Two hundred fourteen (214) articles met inclusion criteria. A variety of methods were used for identification of evidence gaps, but almost 40 percent of articles did not specify how research gaps were identified. Only six (2.8 percent) of the papers cited a previously published systematic review as a source of identified evidence gaps; none of these were AHRQ-sponsored reviews. We focus the rest of the result reporting on the characteristics of the modeling/VOI papers.

Sixty-four of the included articles were categorized as using modeling (including VOI) as the primary method for research prioritization. Studies that were primarily methodological but included specific examples were included. Of these, 60 represented at least one unique analysis (the remainder represented analyses conducted for the UK Health Technology Assessment program that were published both as Health Technology Assessments by the UK government and as peer-reviewed journal articles). Table 2 summarizes the basic characteristics of this subset of articles.

Table 2 Characteristics of modeling and VOI studies

Characteristic | Number of studies | Percentage of studies
Sponsor
UK Government | 22 | 36.7%
National Health Service/HTA program | 19 | 31.7%
Other UK government | 3 | 5.0%
Other European government | 7 | 11.7%
Netherlands | 5 | 8.3%
Other | 2 | 3.3%
Canadian government | 4 | 6.7%
U.S. government | 4 | 6.7%
Foundation or university | 12 | 20.0%
Industry | 7 | 11.7%
Not specified | 4 | 6.7%
Analytic method | | 0.0%
Cost-effectiveness and VOI | 56 | 93.3%
Other | 4 | 6.7%
Purpose of analysis | | 0.0%
Specific technology adaptation vs. value of future research | 52 | 86.7%
Study design | 5 | 8.3%
Research prioritization beyond specific intervention | 3 | 5.4%

Abbreviations: HTA = Health Technology Assessment; UK = United Kingdom; VOI = value of information

The most common sponsor of model-based research prioritization analyses were governments with significant involvement in funding health care delivery (35 of 60), with 22 of these funded by the UK Health Technology Assessment program or another UK government research agency.

The majority of the analyses specifically used cost-effectiveness analysis along with formal VOI analysis. Other methods included cost-effectiveness analysis with sensitivity analysis to identify variables contributing the most to uncertainty, but without explicit VOI estimation;13 combining estimates of population-level utilization of off-label drugs with level of evidence for specific indications to quantify uncertainty;14 combining estimates of cancer incidence and exposure prevalence with rankings of biological plausibility, existing evidence, and sample size estimates;15 and using graph-theoretical methods for research prioritization in malaria control.16

Not surprisingly, given the sponsors, the majority of the analyses were specifically for the purpose of estimating the cost-effectiveness of specific health interventions and the value of future research for specific questions related to those interventions. Five papers17–21 addressed issues of study design, while three14–16 addressed broader research prioritization questions.

## Limitations

Reports of research prioritization methods may be particularly susceptible to biases in the types of articles most likely to be published. For example, approximately 40 percent of the identified articles were focused on research interests of a particular provider or specialty group, often in conjunction with specific meetings or conferences, and were published in journals of interest to that group. Research prioritization processes across broader areas (for example, between cancer and cardiovascular disease, or among breast, prostate, and lung cancer) may be conducted at higher institutional levels with less of a natural audience and publication forum (or no perceived need for publication). Conversely, for methods like VOI, where there is still a significant amount of methodological development, publication venues may be limited to a relatively small number of journals. Processes and methods used by industry may be underrepresented because of proprietary interests.

Our search strategy may have missed decision or cost-effectiveness analyses that suggested priorities for future research based on sensitivity analysis but which did not formally include estimation of VOI.

We did not attempt to assess study quality, mainly because we are unaware of any validated system for rating reports of research prioritization methods. We did not systematically attempt to determine whether any of the VOI or other modeling papers we identified resulted in actual performance of research in priority areas; possible methods for determining this include searches of papers that cited the identified articles, documentation of decisions to adapt or defer adaptation of technologies evaluated, or specific announcements of funding opportunities.

## Discussion

Approximately 40 percent of the articles identified through our search did not specify what method was used to identify research gaps. Perhaps more disconcertingly for producers of systematic reviews, only 6 of 209 cited a previously published systematic review as a source. Given the volume of high-quality reviews generated by the EPC program, the Cochrane Collaboration, and others, this reinforces the need for identifying better methods for ensuring that reviews are identifying evidence gaps in ways that facilitate translation into actual research.

The majority of the modeling/VOI articles identified were focused on questions of whether to adapt a specific health intervention, based partly on cost-effectiveness considerations, and used VOI to estimate the value of specific additional research on questions related to that decision. We did not identify any papers where EVPI estimates for specific conditions were compared to assist in broader research prioritization questions. Even in primarily methodological studies where several VOI case studies were performed,7,22 there was no direct comparison of EVPI estimates across interventions. Given the lack of suitable models for the range of conditions/interventions of interest to most sponsors, this is appropriate, but it does represent a potential area for further methodological development.

Within the context of developing a research agenda on the basis of CERs, the type of focused, specific modeling exercise conducted by the Health Technology Assessment group would be most likely to have direct application. In the work described in the next section, we supplemented our literature review by searching Web sites and directly contacting major institutions involved in research funding for information on internal processes and methods used for research prioritization, again with a specific interest in the extent to which modeling and/or VOI were used for priority setting in the context of “standard operating procedures.”