# Discussion and Recommendations

## Use of Systematic Reviews in Research Priority Setting

Although we did not systematically attempt to quantify the use of systematic reviews in research prioritization, explicit mention of systematic reviews as sources for identification of evidence gaps was rare in either our literature search or review of existing prioritization processes. The most formalized use of reviews was for health technology assessments in the UK, which either directly cited previously conducted reviews as evidence or conducted reviews specifically for the purposes of the technology assessment.

Systematic reviews may play an indirect role in many research prioritization processes that is not captured in published reports or descriptions of standard operating procedures. For example, it seems reasonable to assume that at least some content experts involved in consensus-based processes would be aware of published reviews and incorporate the findings of these reviews, and their interpretation of these findings, into their deliberations. However, we would suggest that, if resources are going to be devoted to formalizing and prioritizing research recommendations arising from systematic reviews in the hope of answering important unanswered questions, then some additional research is needed to identify any barriers beyond the format in which those recommendations are presented. A complex VOI analysis with specific recommendations for research priority areas, appropriate study designs, and optimal sample sizes presented with compelling graphs will not result in closing of evidence gaps if the review is not read and used by stakeholders involved in sponsoring and conducting clinical research.

Because of this, further research is needed into the research prioritization process itself. Although a comprehensive discussion of research into research prioritization is beyond the scope of this report, we believe that maximizing the probability that an EPC report will influence future research requires more than identification of best practices for reporting and prioritizing evidence gaps—identifying and removing barriers to the use of that report by key stakeholders involved in the clinical research enterprise is also needed.

## Use of Modeling and VOI in Research Priority Setting

Although our literature review suggests a growing interest in the application of modeling and VOI to research priority setting, and there is considerable experience in the use of VOI in the UK health system setting, the available evidence does not allow us to draw any inferences about how modeling or VOI compare to other methods for establishing research priorities, either in general or in specific contexts. Even in the setting of the UK Health Technology Assessment (HTA) program, we could not readily determine whether the results of the VOI-based research recommendations have been translated into ongoing or completed studies. Consensus-based processes were the most common type of method in both the literature review and the review of research funders, but there is no clear way to compare the outcomes of these methods to modeling; for that matter, there is no clear agreement on what outcomes can and should be measured in order to assess the comparative effectiveness of different research prioritization methods.

Again, a comprehensive discussion of the issues involved in comparing different prioritization methods is beyond the scope of this report, but, at the simplest level, one would hope that a research prioritization process would ultimately result in the performance of research in the areas identified as highest priority, and that the results of this research would resolve some uncertainty about an important clinical or public health question. As suggested above, there are factors other than the methods used for prioritization which may affect whether the results of a specific process get translated into research results, but, at the least, we would suggest that some effort be directed into development of measures to help evaluate different research methodologies. Some examples of these measures include:

- Measures focused on the process itself. These could include the resources (including both costs and time) required to conduct the process, and feedback from participants in the process and decisionmakers who use the results of the process.
- Specific allocation of resources aimed at the top priority areas. At the intramural level, this can be measured by specific budget line items. At the extramural level, this can be measured by the issuance of specific program announcements, requests for applications/proposals, or other specific solicitations, along with funding levels.
- Performance of research focused on specific priority areas. This can be measured by funded grants/contracts.
- Dissemination of results of prioritized research. This can be measured by meeting presentations, publications, or impact factor of publications.
- Measurable differences in health outcomes or decreased unexplained variation in practice patterns. This can be measured using many of the standard tools of health services research.

## Incorporating VOI into Future Research Needs Assessments for the EPC Program

Although we believe that our two case studies on using modeling with an emphasis on sensitivity analysis (ACEIs/ARBs for IHD) and individual-level VOI analysis (management of uterine fibroids) provided valuable insights into the potential use of these techniques for research prioritization as part of future reviews, it should be emphasized that these were pilot projects with a number of limitations, many of which are described in the sections of the report detailing the studies. In this final section of the report, we summarize the overall general limitations and “lessons learned” and suggest further methodological work (without assigning priority ranks to specific questions).

- Many of the specific issues discussed below—timing and resource allocation issues for model development in the context of a systematic review; availability of appropriate expertise to develop and interpret the model; the role of interaction between modelers, stakeholders, and decisionmakers in model development and interpretation; appropriate education for stakeholders and decisionmakers in the use and misuse of models—were also identified as issues in the Minnesota EPC’s draft review of the general use of models in systematic reviews2 and in the UK HTA program’s assessment of its initial pilot studies of VOI as part of their health technology assessments.7
- Given the extensive and almost exclusive experience of the UK HTA program with VOI, direct consultation with this group should be undertaken if further consideration is given to the potential use of VOI as part of EPC reports.
- As mentioned above, the choice of clinical topics was based on familiarity with the topic, existing models on which to base our analyses, and concurrent related AHRQ-sponsored projects. Our original intent was to conduct full VOI analyses for both topics, including population-level analyses; however, time and resource constraints, including availability of stakeholders, precluded this. Because we used different topics, stakeholders, modeling outputs, and comparator prioritization methods, we cannot draw any inferences about the relative usefulness of sensitivity analysis or individual-level VOI(although this was never our intent). Although VOI is more attractive from a decision theoretical perspective and has the advantage of helping to identify appropriate budgeting levels, the modeling is more difficult and computationally intense, and the interpretation of results, especially for stakeholders unfamiliar with decision analysis and modeling, is more difficult. Further studies of modeling as a tool for research prioritization should allow direct comparison of the relative utility of a simpler versus a more complex approach.
- Because we did not conduct or present “full” VOI analyses, including presentation of population EVPI and EVPPI to the stakeholders, we cannot draw any inferences at all about the potential usefulness of these methods compared to sensitivity analysis or patient-level VOI.
- In both case studies, the time and resources needed to develop useful models was substantial, even though (a) both models were extensions of previously developed models, and (b) our emphasis in both cases was on providing a minimal set of results to introduce stakeholders to potential applications of modeling in priority setting, rather than on detailed and comprehensive consideration of the full range of research options. This suggests that the decision to develop or adapt a model and apply it to research prioritization setting needs to be made relatively early in the systematic review process. Alternatively, if formal research prioritization is a separate process that occurs after the completion of the review, sufficient time must be allotted for model development. This suggestion is consistent with the draft Minnesota report as well.
- One of the challenges in developing models in parallel to the systematic review process is that, although many of the key parameters needed for the model will be identified through the systematic review designed to answer key questions, there will be additional data needs that will likely require additional literature searches or primary data analysis. Identifying the need for these additional data, as well as estimating the resources required to obtain them, can be difficult during the initial development of a proposal, particularly if the need for a model has not been specified.
- One of these additional data needs is likely to be cost data. In both case studies, we required estimates of costs in order to generate cost-effectiveness estimates for sensitivity and VOI analyses. Although it would certainly be possible to use sensitivity analysis to identify those variables contributing to the greatest uncertainty regarding noneconomic outcomes (even using VOI methods without incorporating costs5,6), and to use this information to inform research prioritization, avoiding the use of costs in an exercise that explicitly recognizes the existence of limited resources would require substantial cognitive dissonance, and would make VOI impossible. Use of modeling and VOI as part of research prioritization for systematic reviews would require explicit resource allocation for obtaining relevant cost data, either as part of the review or as part of a subsequent prioritization process.
- Both sets of stakeholders stated that they found the model results helpful. In the fibroids case study, the presented results were roughly concordant with the results of the consensus-based process in which the stakeholders had previously been involved. In this setting, it may have been that having their initial results confirmed by an alternative method increased their certainty about their initial rankings. Because of this (unplanned) concordance, we have no idea how stakeholders would respond to results that differed from their previous rankings. Eliciting these data would require either a much larger sample of stakeholders, so that at least some who had different rankings would be included, or performing enough comparisons across multiple clinical areas so that the frequency of disagreement between model-based and consensus-based rankings could be estimated. If concordance is generally high, then additional work would be needed on the value of stakeholder certainty in generating research recommendations. If concordance is low, then identifying ways to resolve these differences, or to determine which method is more likely to result in research results, is needed.
- Although none of the stakeholders felt that review of model results alone should be used instead of a more traditional consensus-based approach, all felt that the model results were very useful in conjunction with a consensus-based approach, with the participants roughly evenly divided on whether the results would be more helpful as part of the background preparation for the consensus-based approach or as part of an iterative process in parallel with the consensus-based approach. Since when the modeling occurs has significant implications for resource allocation and overall timing of the prioritization process, evaluative studies comparing these two possible approaches in more detail could be useful.
- All of the participants felt that having more background material on modeling and VOI, either directly or as an easily accessible resource, would have been helpful. This need for further stakeholder education was also identified by both the Minnesota EPC and the HTA program. One possible solution would be the development of an EPC-wide reference available via the Web that would provide appropriate background to stakeholders.
- The optimal composition of the stakeholder group and timing of their involvement in the prioritization process is unclear. The Technical Expert Panel (TEP) supporting the systematic review would have familiarity with the clinical area and the state of the available evidence, which might facilitate integration of modeling results into recommendations for future research. However, this potential function of the TEP would need to be explicitly considered during the selection of members to ensure adequate representation by potential decisionmakers. Additionally, if the research prioritization process extended beyond the completion of the systematic review, the longer time commitment for TEP participation would require additional resources and might prohibit the participation of some potentially important experts or stakeholders. The alternative approach, convening a separate group of experts/stakeholders explicitly for the research prioritization process, would ensure the most appropriate membership, but could require additional time and effort in familiarizing the group with the underlying issues.
- Based on these initial pilot studies, we believe that the use of modeling, including VOI, is worth further evaluation as a method for identifying and prioritizing future research needs for reviews conducted as part of the EPC program. We would recommend:
  ○ Incorporating these methods into several new reviews, in order to better assess the incremental costs associated with conducting them.
  ○ Conducting the full range of possible analyses, from sensitivity analysis through population-level estimation of EVPI and EVPPI, for each review.
  ○ Devising methods for assessing the relative costs and effectiveness (in terms of stakeholder evaluations) for the varying types of analyses.