# Current Approaches to Priority Setting: Institutional Perspective

## Methods

Based on discussions among the project team and with AHRQ staff, we identified 48 research-sponsoring organizations for consideration. The list was not meant to be exhaustive, but rather to represent a broad range of organizations involved in funding research activities that would be faced with the issue of prioritizing resources. These included:

- U.S. Public Health Service institutions, including various NIH offices and individual institutes, AHRQ, and the Centers for Disease Control and Prevention.
- Comparable agencies in other countries, such as the UK National Institute for Clinical Excellence (NICE), the Canadian Agency for Drugs and Technologies in Health (CADTH), and the Australian Research Council.
- Organizations involved in a variety of activities aimed at reducing morbidity and mortality from specific diseases, such as the American Cancer Society and the American Heart Association.
- Organizations involved in international research activities across a range of conditions, such as the World Health Organization (WHO), the Cochrane Collaboration, and the Gates Foundation.

Research priority-setting practices at these organizations were identified based on publicly available information (primarily through the organizations’ Web sites), published literature, or by contacting the institutes directly. We contacted 45 selected institutions (see Appendix C) by email, with telephone followup when necessary, on several occasions over a period of 3 months to request additional information on priority-setting practices and to relay our particular interest in information related to modeling or use of quantitative methods in priority setting. We identified priority-setting methods at two organizations (WHO and the Child Health and Nutrition Research Initiative of the Global Forum for Health Research) based on descriptions in the literature without supplemental e-mail or telephone contacts. Material from the organizations (in the form of e-mail or telephone conversations, sharing of formal documents such as procedure manuals, or referrals to publicly available online documents) were reviewed for information related to the focus of the priority-setting method (such as broad organizationwide allocation of resources versus funding of specific projects), the criteria for priority setting, and specific methods used (such as formal consensus-based methods or quantitative analysis). Our focus was on processes and criteria used to prioritize between broad clinical topics (e.g., cancer versus maternal mortality, breast cancer versus colon cancer versus prostate cancer), specific areas within clinical topics (screening versus primary prevention for colon cancer), specific topics within those areas (improved test sensitivity versus improving patient adherence in colon cancer screening), or specific study designs. We did attempt to identify criteria or processes used to decide funding for individual research projects within a given specific area (such as the probability of successfully answering the research question given the information provided in a research proposal). For the purposes of this report, we focus solely on the results relevant to the use of systematic reviews and modeling and/or VOI as part of the prioritization process.

## Results

We were able to determine whether 31 of the 48 research-sponsoring institutions (65 percent) utilized specific priority-setting methods. Of the 17 without information, 12 had no publicly accessible information through published literature or their Web site and did not respond to e-mail or telephone contacts, 3 actively declined to provide information, and 2 responded but the material provided did not describe sufficient details of the prioritization process. The countries represented were the United States, United Kingdom, Australia, Germany, and Canada. The majority of organizations reviewed (26 of 31) described a well-defined priority-setting process.

However, only two organizations reported the use of quantitative or modeling-based approaches. The most explicit use of quantitative methods was by the UK NICE, which recommends use of decision-analytical methods and VOI-based approaches in the framework used to translate uncertainties identified in systematic reviews into both decisions about technology adaptation and recommendations for further research. NICE was also the only organization to explicitly cite systematic reviews as a source for identification of research needs. These detailed assessments for NICE are performed by a network of academic centers under the umbrella of the National Institute for Health Research (NIHR) Health Technology Assessment program. However, the decisions about which topics to consider for reviews are based on a process involving a variety of stakeholders, and it is unclear to what extent modeling/VOI results, even preliminary results, are incorporated into these decisions. Once a detailed review has been performed, the modeling/VOI results and their implications are quite clearly described, but it is unclear by what mechanism those recommendations get translated into the actual performance of research. Among U.S.-based organizations, the U.S. Agency for International Development (USAID) was the only agency that recommended use of analytical tools such as cost-effectiveness and cost-benefit analysis to determine the value of its research efforts. However, in contrast to the situation with NICE, we could not identify specific examples of the use of this USAID recommendation in research priority setting, or even determine whether cost-effectiveness considerations were focused more on the potential cost-effectiveness of the interventions being studied, rather than the cost-effectiveness of the research itself.

## Limitations

The list of 48 research-sponsoring organizations we reviewed was neither exhaustive nor random.

Our sample was biased toward developed country organizations with English-language Web sites, although this likely reflects actual funding patterns for health research. Individual institutes and offices of the NIH in the United States accounted for the majority of organizations represented. We did seek information from major sponsors of health research in developing countries, such as the Gates Foundation and WHO. We did not attempt to elicit information on research priority-setting practices from within industry.

## Discussion

Our findings were qualitatively quite similar to those of a 2007 systematic review of priority-setting processes among organizations performing health technology assessment.23 In particular, the authors of the 2007 assessment found that, although almost all of the 12 organizations reviewed included economic considerations as a criterion for conducting a technology assessment, only 2 explicitly considered the efficiency of actually conducting the research—in other words, the value of further information, whether formally modeled or considered in a more semiquantitative way.

Only the UK NICE, through the NIHR Health Technology Assessment program, described a topic identification process that included an explicit process that included ongoing surveys of the literature. This suggests that, for many organizations, the potential for evidence gaps identified by a given systematic review/evidence report to be incorporated into a research prioritization process depends on the degree to which the stakeholders involved in the prioritization are aware of the review’s results and consider them valid. If the majority of current research prioritization activities are taking place without systematic consideration of the results of reviews, then consideration of whether specific methods for presenting and prioritizing research gaps would improve translation into active research may be premature—a more pressing issue would be how to ensure that decisionmakers and stakeholders were even aware of the review’s existence.

We identified only one organization that explicitly used modeling-based approaches, specifically cost-effectiveness analysis and VOI analysis, in its research priority setting. Not surprisingly, given the findings of the literature review, this was the UK NICE. In contrast to many of the other organizations, NICE is tasked with making recommendations about adaptation of specific technologies and further research into those specific technologies, rather than making recommendations across broader areas of research (for example, relative allocation of research funds for breast versus prostate cancer). These analyses are usually conducted within the context of specific systematic reviews. The combination of a “menu” of highly specific potential research questions and a context where costs and cost-effectiveness are explicitly part of the decisionmaking process facilitate the potential applicability of VOI to research priority setting. In this context, it is interesting that the only U.S.-based organization that explicitly included cost-effectiveness considerations in its criteria was USAID, which is focused on research in resource-poor settings.

However, there is a subtle distinction to be made. The process by which NICE selects topics for review involves a number of steps and stakeholders. Although “horizon scans” by the National Institute for Health Research (NIHR) Health Technology Assessment program are part of this process, there are a variety of stakeholders involved, and other methods are used. The NIHR, through a network of academic centers, conducts reviews that include modeling and, frequently, VOI, and these reviews inform recommendations for technology adaptation and future research. The degree to which modeling and VOI are incorporated into the initial topic selection by NICE itself is unclear. The technology assessments including VOI provide research prioritization, but the degree to which these are translated into actual research, under whose auspices, and by what mechanism, are also not clear from our review of NICE’s publicly available materials.

Our systematic literature review and nonsystematic review of research-sponsoring organizations found that systematic reviews are rarely explicitly used as part of the research prioritization process, and substantial practical experience in the use of VOI for prioritization is largely limited to NICE.

In order to explore the potential use of modeling and VOI in research priority setting for CERs conducted under the EPC program, we conducted two pilot case studies involving EPC reports that included models as part of the report. As mentioned above, the topic areas for these case studies were chosen because of previous or concurrent work, including modeling, by the Duke EPC in these content areas and, in the case of the uterine fibroids study, a concurrent AHRQ-sponsored project to develop a consensus-based research agenda on comparative effectiveness research for management of fibroids.