# Case Study: Uterine Fibroids

## Background

Uterine leiomyomata, or fibroids, are benign tumors of the uterine smooth muscle and extracellular matrix and are extremely common in women of reproductive age. Using sensitive imaging techniques, cumulative incidence is as high as 70 percent among white women and more than 80 percent among African -American women by age 50.^46^ Most fibroids are asymptomatic; however, in those women with symptoms such as pain or heavy menstrual bleeding, there are limited treatment options. Hysterectomy is curative (in fact, fibroids are the leading indication for hysterectomy in the United States), but there is significant interest in identifying effective alternatives to hysterectomy.1,12,47,48 Given the high burden of disease (including substantial medical and nonmedical costs49,50), significant differences in treatment choices and outcomes among population subgroups, local variation in rates of certain treatments such as hysterectomy,51 and a range of medical and invasive treatments, management of uterine fibroids is an obvious area for comparative effectiveness research.

The Duke EPC conducted a systematic review on management of fibroids in 2001 that concluded that there was essentially no high-quality evidence available for making decisions regarding the most appropriate treatment for specific patients.12 As part of the report, there was a detailed list of suggested research questions to address the existing evidence gaps. Subsequently, the Research Triangle Institute/University of North Carolina at Chapel Hill (RTI/UNC) EPC conducted an update in 2007 and noted that “[t]he current state of the literature does not permit definitive conclusions about benefit, harm, or relative costs to help guide women’s choices,”48 with little change noted in the identified evidence gaps.

In 2009, AHRQ awarded a contract to the Outcome DEcIDE Center to develop a specific research agenda for comparative effectiveness research for management of uterine fibroids.1 As part of this process, Outcome, working with the Center for Medical Technology Policy (CMTP), conducted a priority-setting exercise with a number of stakeholders; Dr. Myers served as co -chair of the Technical Working Group for this project. The large stakeholder meeting took place in March 2010. Because the Duke EPC had developed a decision model as part of the original 2001 report, which was also led by Dr. Myers as principal investigator (PI), the coincident timing of the AHRQ fibroid research agenda project and this project on broader issues in priority setting allowed us to incorporate a pilot exercise comparing the results of the modified Delphi process used with the large group of stakeholders to a formal decision model/VOI analysis.

## Methods

### Simulation Model

The model is a substantial update of one developed for the 2001 Duke EPC Evidence Report on management of uterine fibroids.12 At that time, we concluded that “the lack of data necessary to validate, calibrate, and test this model is striking,” although we were able to perform a relatively simple “proof-of-principle” analysis comparing relief of symptoms with watchful waiting, hysterectomy, or myomectomy (removal of the fibroids themselves while preserving the uterus). In sensitivity analysis, the main drivers of effectiveness were the probability of menopause and the likelihood of development of new symptoms after hysterectomy.

Our updated model is structurally similar to the previous one (Figure 3). Details of the model structure, assumptions, input parameters, and the rationale for our choices are described in detail in Appendix F. Although we attempted to make the model structure as flexible as possible to allow further development as a tool in fibroids research, our focus was primarily on the stakeholders’ perceptions of the potential usefulness of the VOI analysis in priority setting rather than on the results of the VOI analysis themselves. In addition, we had time and resource constraints that were similar to those that would be operational if a model were done as part of a CER. Because of this focus and these constraints, we simplified the model and the analysis in a number of ways to facilitate timely completion of the analysis and reasonably simple presentation to the stakeholders

Figure 3 Schematic diagram of fibroids model

Figure 3 Schematic diagram of fibroids model is structurally similar to Figure 3. Details of the model structure, assumptions, input parameters, and the rationale for our choices are described in detail in Appendix F. Although we attempted to make the model structure as flexible as possible to allow further development as a tool in fibroids research, our focus was primarily on the stakeholders’ perceptions of the potential usefulness of the VOI analysis in priority setting rather than on the results of the VOI analysis themselves.

Although population-level values for EVPI and EVPPI would be preferable for purposes of decisionmaking about research investments, we focused this initial analysis, including the results presented to the stakeholders, on individual-level EVPI and EVPPI. Although most of the recent examples of the use of VOI in research prioritization have focused on population-level values, individual level EVPPI can be also be used as a form of sensitivity analysis.5,6,10,52–54 We chose this approach for several reasons:

- As discussed in the detailed description in Appendix F, the model itself is still something of a work in progress, particularly regarding the potential interaction between the natural ovarian aging process as women approach menopause and treatment efficacy. In addition, the potential impact of incorporating reproductive outcomes into assessing treatment effectiveness for fibroids has not been previously explored. Because of this, we wanted to gain preliminary insight into structural aspects of the model, both to set the stage for further development and to be able to put the results in context for the stakeholders.
- Our primary goal in this case study was to obtain some sense from stakeholders about the potential utility of simulation modeling/VOI as part of a research prioritization process, especially in comparison to the recently completed consensus-based process.1 Our experience working with stakeholders (or reviewers) with primarily content expertise who are unfamiliar with modeling is that considerable time and effort must be spent on explaining the underlying model structure and assumptions, and providing as much information as possible to ensure confidence in the face validity of the model. By being able to explain how different clinical or epidemiologic parameters affected the per-patient EVPI or EVPPI, we were able to demonstrate that many of the results were consistent with our current understanding of fibroids management.
- Although study feasibility was one of the factors stakeholders were asked to consider during the consensus-based priority setting, explicit discussions about sample size or available budget for specific research areas were not a major part of the process. We were most interested in comparing the relative ranking from the model-based analysis to that generated by the consensus-based process, which we were able to do with patient-level values. Incorporating population-level values would have provided additional information beyond the relative rankings and would certainly be helpful in discriminating between the highest ranking areas.
- There is uncertainty about the size of the potential affected population to be used for population-level estimation. A substantial number of procedures are performed on an outpatient basis, but, because of a lack of national data on outpatient procedures and substantial regional variation in the ratio of inpatient to outpatient procedures,1 reliable estimates are difficult. Although an inpatient-based value would provide a lower bound and would be reasonable for the purposes of EVPPI comparisons, we elected not to incorporate this additional level of uncertainty for the purposes of the pilot exercise.

Briefly, the model is a Markov simulation that begins immediately following treatment for symptomatic fibroids. The model uses 1-week cycles and follows women for 3 years (based on the available long-term data on treatments of interest) or until age 45. We chose to stop the simulation at age 45 both because we were interested in pregnancy, which is rare after age 45, and to avoid the need to develop a method for modeling the interactions of natural menopausal changes in ovarian function and treatment effects, given our project timetable. We compared outcomes after myomectomy, uterine artery embolization (UAE), or magnetic resonance imaging (MRI)-guided focused ultrasound (FUS), based on published results (but not from a formal systematic review). We chose these three treatments based on current treatment patterns and interest expressed at the larger stakeholder meeting. We did not include long-term complications in the model, both to simplify modeling and presentation and because of a lack of data.

Our primary focus was on several broad areas at the top of the priority list identified by the larger stakeholder group—reproductive outcomes, relative recurrence rates, and the impact of recurrence on quality of life. In order to simplify both the analysis and the presentation, we did not attempt to model all of the possible options for managing recurrent symptoms. Instead, “recurrence” was an absorbing state in the model, with a wide range of possible costs and utilities associated with having recurrent symptoms.

The model was run as a microsimulation, using an age and racial distribution similar to a large prospective registry of women undergoing UAE,55 and using age- and race-specific probabilities and nonmedical costs as described in detail in Appendix F. For each analysis, we performed between 600 and 10,000 simulations, drawing from the described distributions for each variable. We first performed a cost-effectiveness analysis from a societal perspective, using incremental cost/QALY as the primary outcome, followed by probabilistic sensitivity analyses using net monetary benefits across a range of willingness-to-pay thresholds from $0 to $100,000/QALY. We then estimated the EVPI for the entire model, followed by the EVPPI for individual variables or groups of variables. This was done by “fixing” the value (usually at the mean) of the variables of interest, then repeating the microsimulation using the remaining variable distributions. The EVPPI values for selected variables of interest were then ranked in descending order. Again, given time constraints, we did not estimate EVPPI for all possible variables, but focused on those identified as important by the modified Delphi process described below. As discussed above, we focused on the effects of different parameters on individual-level EVPPI in our initial review and interpretation of results, and in our presentation to the stakeholders.

### Modified Delphi Process (by Outcome DEcIDE Center and CMTP)

The process used to develop a research agenda is described in detail in the Outcome report.1 Briefly, a Technical Working Group (TWG) subcommittee of eight members with expertise in various aspects of fibroid research and treatment was assembled to provide technical expertise and develop a relatively focused group of research questions for discussion by a larger Stakeholder Committee of 34 members.

The TWG narrowed the list of evidence gaps identified from previous systematic reviews, translated these gaps into specific research questions, identified ongoing or planned studies that were relevant to specific questions, and helped develop background materials for the larger group. First, the TWG scored the initial list of questions using priority-setting criteria developed by Outcome and CMTP. The TWG then met to discuss and refine the questions, followed by rescoring. Based on this second scoring, a list of the top 12 research questions, along with general and question-specific background materials, was distributed to the larger Stakeholder Committee.

The Stakeholder Committee’s main objective was to generate a ranked list of research questions related to management of uterine fibroids. Each question was presented by a member of the TWG, with opportunities for discussion and questions. At the end of the meeting, members voted and generated a prioritized research agenda for uterine fibroids.

### Comparison of Modified Delphi Process and VOI

We invited nine stakeholders who had participated in the earlier process to review the results of our VOI analysis and provide feedback on the usefulness of the VOI. These stakeholders were selected to provide diversity of backgrounds and included a gynecologist, an interventional radiologist, a health economist, a patient advocate, an endocrinologist working in industry, a representative from a large third-party payer, the Principal Investigator of the Outcome project, and representatives from the National Institutes of Health (NIH) and AHRQ.

The stakeholders were provided background materials prior to the call, including the detailed description of the model included as Appendix F and several review articles on VOI analysis, as well as a copy of the slide presentation given during the conference calls.

Three 1-hour conference calls were held to accommodate schedules, during which the a slide presentation was given which covered:

- The background of the project and the main purposes of the project—specifically, to assess the feasibility of VOI in a clinical area with a notably low level of quality evidence, to get input from them on the potential utility of VOI as a substitute or complement to the consensus-based process, and to get input on the optimal timing of VOI if done as part of a larger, multimethod priority-setting process.
- A brief description of the model and the use of sensitivity analysis as a technique to quantify the impact of different parameters on outcomes
- A brief definition of cost-effectiveness and net monetary benefits
- A brief description of VOI, which introduced the concepts of EVPI and EVPPI. Specifically, stakeholders were told that VOI was a method for estimating the value of future research, that population-level values could be used to generate research budgets, and that EVPPI was a method for ranking the relative importance of individual parameters within the model.

Each call was recorded and stakeholder feedback elicited. A brief survey was subsequently sent to the stakeholders to provide an opportunity for further structured feedback. Given the small numbers of participants, we did not formally quantify survey responses.

## Results

### Model Results

We emphasize that these results are preliminary and that further model refinement and additional analyses may change the results.

Table 5 presents the mean and standard deviations for expected recurrences and reproductive outcomes from the initial model runs, assuming that 25 percent of patients would attempt pregnancy within the first year after treatment and that there are no differences between treatments on reproductive outcomes.

Table 5 Expected recurrences and reproductive outcomes from initial model runs

Outcome | Treatment
Outcome | UAE | | Myomectomy | | FUS
Outcome | Mean | SD | Mean | SD | Mean | SD
Recurrence | 0.095 | 0.924 | 0.082 | 0.275 | 0.225 | 0.412
Pregnant | 0.087 | 0.282 | 0.097 | 0.296 | 0.085 | 0.228
Live birth | 0.055 | 0.228 | 0.063 | 0.243 | 0.055 | 0.222
Preterm birth | 0.012 | 0.110 | 0.014 | 0.111 | 0.012 | 0.104
% Preterm | 22.4% | - | 21.8% | - | 22.0% | -

Abbreviations: FUS = focused ultrasound; SD = standard deviation; UAE = uterine artery embolization

The high degree of uncertainty in the parameter estimates is reflected in the very wide standard deviations. Not surprisingly, pregnancy and live birth rates were relatively low, and preterm birth rates were high. Women in their 30s and 40s are less likely to get pregnant and more likely to have a miscarriage, resulting in low live birth rates, while African-American women, who make up approximately half of the population of women receiving fibroids treatment, are more likely to experience preterm delivery, especially at older ages (for example, a 44-year-old black woman is three times as likely to have a preterm delivery than a 25 -year-old white woman—see Appendix F). The low pregnancy rates create a challenge for studying the effect of different fibroid treatments on reproductive outcomes, since a very large number of women actively seeking to get pregnant would be needed to identify clinically meaningful differences in outcomes. In order to simplify the analysis and presentation, we elected not to further explore the potential impact of differences in treatments on reproductive outcomes in the VOI analysis—the only pregnancy-related variable left in the model was time between initial treatment and the start of attempts to achieve pregnancy. We kept this variable because it was independent of any treatment effects on reproductive outcomes and, given our underlying assumptions, pregnancy and recurrent symptoms were important competing risks.

The overall EVPI per patient for the model as constructed ranged from $1,050 at a willingness-to-pay threshold of $50,000/QALY to $1,460 at a threshold of $100,000/QALY, reflecting the high degree of uncertainty for most of the model parameters. Table 6 shows the results of the EVPPI for selected variables:

Table 6 Patient-level EVPPI for selected variables

Parameter | EVPPI
Utility after retreatment | $1,053
Time to return to work | $1,047
Time before trying to get pregnant | $1,046
Relative recurrence rates | $1,043
Time between recurrence and retreatment | $1,038
Cost of complicated cases | $1,037
Length of stay (mean of uncomplicated and complicated cases) | $1,030
Cost of uncomplicated cases | $9.50

Abbreviation: EVPPI = expected value of partial perfect information

The majority of the variables considered had EVPPIs close to the overall EVPI, and given the high degree of uncertainty, the observed differences in the estimates may well be insignificant. However, factors related to recurrence and quality of life after recurrence were major drivers of uncertainty.

We then compared the overall EVPI for different mutually exclusive subpopulations of interest—first, white versus African-American women, and, second, women who desired future pregnancy versus those who did not (Figure 4). The overall EVPI across the range of willingness-to-pay thresholds was slightly lower for white women than for African-American women. The major modeled differences between white women and African-American women were older age, higher wages, and overall better reproductive outcomes for white women; we did not model other consistent differences, such as more severe symptoms and more extensive disease among African-American women. Given that we constrained the simulations to 3 years or reaching age 45, the lower overall EVPI for white women likely reflects an older mean age, resulting in a greater number of women reaching the end of the simulation before an opportunity for recurrence.

Figure 4 Expected value of perfect information (EVPI) in select subpopulations of patients

(A) white women vs. (B) African-American women, and (C) women desiring future pregnancy vs. (D) women who have completed childbearing. WTP = willingness-to-pay. Comparisons are valid only between mutually exclusive groups—A vs. B and C vs. D.

Figure 4 shows the expected value of perfect information (EVPI) in select subpopulations of patients compares overall EVPI for different mutually exclusive subpopulations of interest—first, white versus African-American women, and, second, women who desired future pregnancy versus those who did not (Figure 4). The overall EVPI across the range of willingness-to-pay thresholds was slightly lower for white women than for African-American women. The major modeled differences between white women and African-American women were older age, higher wages, and overall better reproductive outcomes for white women; we did not model other consistent differences, such as more severe symptoms and more extensive disease among African-American women. Given that we constrained the simulations to 3 years or reaching age 45, the lower overall EVPI for white women likely reflects an older mean age, resulting in a greater number of women reaching the end of the simulation before an opportunity for recurrence.

Differences between women desiring pregnancy and those not were much more substantial, with the EVPI for women desiring pregnancy less than half that for women not desiring pregnancy across all levels of willingness to pay. This is largely because, based on our initial results showing an overall low event rate for pregnancy outcomes, we did not model potential treatment-specific differences in reproductive outcomes in this iteration of the model—incorporating uncertainty about the relative impact of different treatments on reproductive outcomes would likely have had a significant impact on the EVPI for this population. Our assumptions that women would not attempt pregnancy while experiencing recurrent symptoms (and, conversely, that recurrent symptoms would not occur during pregnancy), and that a successful pregnancy had a utility similar to relief from symptoms, likely also played a role. Under these assumptions, pregnancy is a competing risk for recurrence, so that overall recurrence rates are lower, and subsequent quality-adjusted life expectancy is higher, among women attempting pregnancy. Since the EVPPI analysis showed that factors related to recurrence were the largest drivers of uncertainty, it is not surprising that the overall EVPI would be lower for a subgroup where recurrence risk is inherently lower. This competing risk effect also explains why time to attempt pregnancy was one of the highest ranking variables in the EVPPI analysis.

### Comparison of Model Results to Qualitative Exercise

The top five research priorities identified by the Stakeholder Committee at the end of the modified Delphi process1 were:

1. What is the relative effectiveness of available interventional procedures (e.g., UAE) on durability of symptom relief and patient-reported outcomes?
2. What is the relative effectiveness of interventional procedures versus noninterventional approaches as initial therapy on durability of symptom relief and patient-reported outcomes?
3. Can we create validated and reliable classification systems of standard anatomic staging to use in research and clinical care of women with uterine fibroids?
4. Can we create validated and reliable classification systems of patient-reported outcomes (including patient preferences, disease-specific and general quality of life, and patient satisfaction) to use in research and clinical care of women with uterine fibroids?
5. Can we create validated and reliable classification systems of measures of responses to specific symptoms (such as menstrual pictograms, menstrual diaries, hemoglobin) to use in research and clinical care of women with uterine fibroids?

As discussed above, the variables with the highest EVPPI were those related to recurrence and quality of life (in this case, utilities) after recurrence, suggesting relatively close agreement between the VOI analysis and the modified Delphi process in terms of the highest priority areas for future research. Because we did not exhaustively include all possible variables in the analysis, and because the EVPPI values themselves are quite similar, it is possible that this concordance may not be so close with further model development. Three of the top five topics related to development of classification/staging systems for use in comparative effectiveness research in fibroids; although we did not model measurement/classification, extending the model to include these types of parameters is certainly possible (for example, by considering an anatomic staging system as a type of prognostic test, and modeling uncertainty surrounding sensitivity, specificity, and reproducibility).

### Stakeholder Feedback

In feedback provided during the conference calls and via written comments, all the stakeholders stated that the VOI exercise was useful. Common themes mentioned included:

- While none of the stakeholders felt that VOI was a substitute for the consensus-based process, all felt that VOI would be a useful complement, with the results either available as background material prior to the in-person consensus meeting, or with the VOI process being done independently and in parallel with a consensus-based process. One respondent noted that the results of a VOI analysis would be helpful in identifying specific decisions that had implications for research feasibility and design, which in turn would be helpful in focusing discussions among a diverse group of stakeholders.
- There was unanimous agreement that the most valuable aspect of the exercise was the opportunity to discuss the model and analysis with the analysts and other stakeholders. The actual results in terms of ranking of research priorities and relative quantification of different areas of uncertainty were also valuable. Although the details of the underlying model were useful to most respondents, this was of overall less importance.
- All of the respondents felt additional background material on VOI, either as a briefing document or an online resource, would have been helpful.

## Limitations

### Model and Results

As stated above, our focus in this exercise was on updating the preexisting model sufficiently to allow conducting a limited VOI analysis for purposes of presenting those results, both alone and in the context of the results of an independent consensus-based research priority-setting process, to a select group of stakeholders with relatively limited experience with the concepts of cost-effectiveness analysis or VOI analysis. Given this focus and time and resource constraints, we made a series of decisions, detailed above and in Appendix F, which limit the direct applicability of these results to priority setting for research on uterine fibroid management. These include:

- Our sources for parameter estimates were not based on a formal systematic review, or on analytic methods such as network meta-analysis, which would have been preferred for generating comparative estimates across three different treatment options.56,57
- We did not include all possible treatment options, including hysterectomy and medical therapies, in the analysis. We also simplistically modeled recurrence—a more sophisticated approach would be to include a range of possible treatment options for recurrent symptoms.
- We did not exhaustively estimate EVPPI for every variable in the model.
- We constrained our analysis to 3 years of followup or reaching age 45. It is possible that longer time horizons would have affected our results, and it is likely that incorporating a potential interaction between treatment effects and declining ovarian function with age would have had some substantial effects.
- We did not model potential differences between treatments on reproductive outcomes. It is likely that uncertainty surrounding these results would affect the EVPI for the minority of women who are interested in future pregnancy.
- We did not estimate population-level EVPIs as part of the formal analysis, for the reasons described above. We provide one overall preliminary estimate below for overall research into management of fibroids, but this is itself subject to the uncertainty surrounding the size of the affected population. Our estimates of EVPI for subpopulations, or our estimates for individual EVPPI, have more value at this point as indicators of how individual components of the model (differential age distribution between subpopulations, competing risks between pregnancy and recurrence, constraining the simulation to women under 45) are driving affecting the outcome, rather than as formal estimates of the upper limit of research funding for a particular area for further research.
- Overall population-level EVPI estimates would have allowed comparison of the value of future research in fibroids to future research in other clinical areas.

### Comparison to Modified Delphi Process

Similarly, our comparison to the modified Delphi process used by the Outcome/CMTP team was limited by a number of factors:

- Our choice of topic was driven by the presence of a preexisting model, institutional experience with the topic, and serendipitous timing. However, because of the size and number of evidence gaps for this particular clinical area, the model resulted in large and closely clustered EVPPIs for a majority of the variables considered. A topic with more discrete evidence gaps might have resulted in more clear-cut model results, and allowed a more detailed comparison to the consensus-based results.
- Our stakeholder group was limited in size, due to both resource and regulatory constraints. Broader representation among the entire stakeholders would have been extremely helpful to get a better sense of the potential utility of VOI. The small sample size also precluded any quantitative assessment of stakeholder perceptions of VOI.
- Dr. Myers, who did most of the model development and analysis, was also chair of the TWG for the consensus-based process. Although his familiarity with the clinical topic, the underlying evidence gaps, and the workings and outcomes of the consensus-based process undoubtedly helped facilitate the VOI process, it is possible that an analyst less involved in the alternative process would have produced results which differed in some meaningful way from the current results.
- Although our top rankings were similar to those resulting from the modified Delphi process, it is possible that at least some of that agreement is due to decisions about the scope and structure of the analysis made in order to facilitate the comparative process. Comparison of results from a more fully developed model to those from the consensus-based process will be informative.
- Our results as presented emphasized the use of VOI as a type of sensitivity analysis for comparison of relative importance of different parameters. Providing population-level estimates of EVPI and EVPPI to the stakeholders, as would have been done in a fully developed VOI analysis, might have resulted in different feedback from the stakeholders.

## Discussion: Fibroids Case Study

### Simulation Model Results

Although we do not believe the model results as presented are directly applicable to priority setting for uterine fibroids, the model does provide some valuable insights:

- The prioritization of specific areas for research is likely to differ between women interested in future pregnancy compared to those who have completed childbearing.
- Sample sizes required to determine differences in reproductive outcomes between treatments are likely to be fairly large.
- The overall EVPI for fibroids appears to be quite large. Comparison of EVPI results across different areas is difficult for a number of reasons, especially in this case where the model is still a work-in-progress. In one of the few VOI analyses conducted for a U.S. population, Hassan and colleagues52 estimated an EVPI for colorectal cancer screening of $216 per subject, less than 25 percent of the estimated values calculated here. One obvious next step after further model refinement is to estimate the population EVPI, which is a function of the expected number of patients affected, the expected duration of use of a given treatment or treatments, and the societal discount rate.58 In the 2007 Nationwide Inpatient Sample, there were approximately 250,000 admissions with procedures performed for a primary diagnosis of uterine fibroids,1 which, given the increasing use of outpatient treatments, is likely an underestimate of the potential population. Assuming another 20 percent of cases done as outpatients (approximately 300,000 patients annually) and a 3 percent annual discount rate, the population EVPI based on our preliminary results ranges from $1.5 billion over 5 years at a willingness-to-pay threshold of $50,000/QALY to $3.8 billion over 10 years at a threshold of $100,000/QALY (the comparable 5-year population EVPI for colorectal cancer screening, which affects approximately 15 million people annually, was $15 billion52).

Specific areas for further model refinement include:

- Incorporating uncertainty about relative treatment effects on reproductive outcomes.
- Incorporating the effect of natural menopause, as well as any interactions between treatment and declining ovarian function.
- More precise delineation of parameter distributions through collaborations with researchers with appropriately large datasets.
- Estimation of population-level EVPI for subpopulations and EVPPI for model parameters.

### Comparison to Modified Delphi Process

The results of our VOI analysis, in terms of ranking of areas of uncertainty, were concordant with the areas of highest priority identified through the modified Delphi process used by the Outcome/CMTP group to develop a research agenda for comparative effectiveness research for fibroid management. It is possible that this agreement is at least partially due to decisions made about the scope and structure of the analysis in order to facilitate this specific comparative project, and comparison of these results to those from a more fully developed model is in order. We also emphasize, as noted above, that the actual differences between specific EVPPIs are quite similar, and it is possible the relative ranking might change with additional model refinement. Despite these and the other limitations discussed above, the stakeholders who reviewed these results felt that VOI analysis had the potential to be a valuable part of any research priority-setting process, primarily either as background or in parallel with a more traditional consensus-based approach.

We discuss the potential implications of these results for incorporation of VOI into future research needs assessments, along with suggestions for further methodology development, in the next section.