# Background

## Identifying and Prioritizing Future Research Needs in Comparative Effectiveness Reviews

The standard for nonindustry-funded biomedical research in the United States, as exemplified by the National Institutes of Health (NIH), has long been: (a) investigator-initiated ideas submitted for peer review almost entirely on the scientific value of the proposal; followed by (b) another layer of peer review at the NIH Council level, where funding decisions are based primarily on the scoring of the initial peer review; followed ultimately by (c) further peer review at the publication and grant renewal stages. As stated by an official at an NIH institute, “The National Institute… strongly believes that the best research relies on the creativity, interests, and expertise of individual … researchers, and investigator-initiated research remains the cornerstone of discovery and innovation in understanding and treating [diseases of interest to the Institute].” This model has been highly successful in generating major improvements in both scientific knowledge and human health.

There are some underlying implicit assumptions behind this somewhat entrepreneurial model:

- Through the literature and other means of scientific communication, the community of researchers will be able to identify the areas of greatest need and opportunity.
- Although research sponsors can provide some direction to specific areas of research through specific program announcements, requests for applications, or other set-asides, the greatest likelihood of significant advances will occur through the generation of multiple ideas, with competition between researchers for funding, publication priority, and other rewards associated with scientific success leading inevitably to progress.
- The most important or valuable “next steps” research will occur either because those next steps are obvious from the current state of the literature, or because less important steps failed to make it through the peer review process.
- The incentives and disincentives for participants in this “market” will align in a way that efficiently results in scientific progress.
- The size of the “market” in terms of number of researchers and available resources will be sufficient to ensure that the probability of progress in important areas will be reasonable.

Despite the overall success of this model in generating scientific advances, dependence on the inherent ability of the scientific marketplace to produce an efficient, steady progression in our ability to prevent and treat disease may fall short in conditions where the underlying assumptions may not be valid. In settings of limited resources, limited numbers of available researchers, or misaligned incentives, there may insufficient numbers of investigators generating competitive proposals to make necessary progress. Mechanisms for communicating specific important next steps may not result in a critical mass of researchers working on those next steps.

The systematic reviews conducted as part of the Evidence-based Practice (EPC) program invariably identify evidence gaps that need to be closed in order to make informed decisions about public health policy and clinical care; many of these reviews explicitly suggest “next-steps” research. In the traditional model of biomedical research in the United States, dissemination of these descriptions of research opportunity through the usual channels for scientific communication would lead to a number of investigators, perhaps gently prodded by a Program Announcement or other indication of sponsor interest, proposing high-quality research which, through the peer review mechanism, would result in fewer evidence gaps identified in a subsequent review. However, this approach is clearly not working consistently for all reports. For example, despite a clear description of important evidence gaps in a 2001 evidence report on uterine fibroids and several relevant federal funding opportunities in the interim, followup reviews in 2007 and 2009 did not identify any substantial progress.1

To help determine best practices for capitalizing on the knowledge gained from systematic reviews to accelerate the development of the evidence base, the EPC program is pursuing several methodological research studies, as well as a set of case studies. Each of the eight EPCs funded through the American Recovery and Reinvestment Act of 2009 (ARRA) – Comprehensive EPC Comparative Effectiveness Reviews for Effective Health Care task order undertook preparing a pilot future research needs report based on an existing Comparative Effectiveness Review (CER). The pilot studies used diverse methods for each step in the process, and guidance from the EPC program on how best to perform these studies is still needed. Although the pilot projects provided case studies of potential methods to employ, formal exploration of the available methods for future research needs identification and prioritization are required. In the present report we explore the use of model-based quantitative sensitivity analysis and value-of-information (VOI) analysis as a tool for prioritizing future research needs. The ultimate goal of this report, as well as the reports by other EPCs that are part of the larger ARRA project, is to assist the Agency for Healthcare Research and Quality (AHRQ) in identifying improved ways to encourage the narrowing of evidence gaps identified through systematic reviews conducted as part of the EPC program.

## Models as Tools for Identifying and Prioritizing Research Needs

As part of the EPC program’s assessment of methods for addressing future research needs, the University of Minnesota EPC recently conducted a review (currently available only in draft form) of the use of decision and simulation modeling in systematic reviews.2 The draft report provides an outstanding overview of the use of models in the literature and within the EPC program and is especially clear on the challenges and potential of incorporating modeling into CERs. Since all of these challenges are true for the use of modeling as a tool for research prioritization, we will discuss these aspects of the report in more detail in the final section on Recommendations.

For the purposes of this report, we define a “model” using concepts similar to those outlined in the draft Minnesota report, namely, as an analytic framework for addressing a clinical or health policy decision that involves the use of:

- Data from a variety of sources;
- The application of specific mathematical techniques to synthesize the data;
- Explicit recognition and estimation of the effect of uncertainty in parameter estimates on the optimal decision.

For most CERs, this will involve modeling both the underlying natural history of the disease, either explicitly or implicitly, and the potential impact of the interventions of interest—such as screening or diagnostic tests, medical therapy, or surgery—on disease natural history, as well as on potential other outcomes of the intervention such as adverse events.

One of the more powerful aspects of the use of modeling is the ability to assess the impact of uncertainty surrounding the values of specific parameters—for example, rates of disease progression, treatment efficacy, adherence to treatment, test sensitivity and specificity, costs of treatment, or productivity losses from illness—on the outcomes being estimated with the model, and whether different parameter ranges alter the optimal decision under a given set of decision rules. This technique, called sensitivity analysis, is a crucial component in any model-based analysis.

Depending on the model and the availability of appropriate data, sensitivity analysis can be done either deterministically (by sequentially varying the value of a given variable or set of variables across the range of potential values) or probabilistically (by running a series of analyses drawing the value of the selected variable or groups of variables from a distribution). Both approaches are subject to limits on the availability of appropriate data and the need to consider potential correlations between parameters. Although the probabilistic approach is preferred in many cases, the need to specify parameter distributions, even in the absence of available data, as well as the additional computational time needed, present additional challenges.

For assisting in research prioritization, sensitivity analysis can be used in two different ways. First, the relative contributions of individual parameters of interest to uncertainty surrounding outcome estimates and the optimal decision can be ranked along two dimensions: quantitatively (those variables that result in the largest range of outcome estimates when varied across the range of reasonable values for each variable) and qualitatively (those variables that result in a change in the optimal decision at some point within the range of reasonable values for that variable).

Although “simply” performing a sensitivity analysis for identifying the most important variables has potential as a tool for research prioritization, there are several major limitations to this approach. First, there is not a standardized way to synthesize the information on both the quantitative size of the effect of parameter uncertainty and the impact of parameter uncertainty on the optimal decision—for example, it is possible that varying the value of a specific parameter across the range of plausible values could have a relatively small impact on outcomes, but that the optimal decision might change somewhere within that range. “Simple” sensitivity analysis also does not account for the potential costs of further research. These costs include not only the resources required to perform the research, but also the costs involved in putting off a decision to adopt an intervention that is truly beneficial, as well as the costs of making the wrong decision. The costs, and ultimately the cost-effectiveness, of future research can be estimated by extending traditional sensitivity analysis into VOI analysis.

Although VOI has been applied in a variety of non-healthcare settings3,4 and can be considered purely as a method for sensitivity analysis,5,6 it has been developed most fully for medical and public health interventions by the United Kingdom (UK) National Health Service Health Technology Assessment program;7,8 the framework used in that program is briefly summarized here.

Simulation models are used to estimate the effectiveness and cost-effectiveness of a particular intervention or interventions, and probabilistic sensitivity analyses are performed. Using this approach, the probability that a given intervention will be cost effective at a given willingness-to-pay threshold can be estimated. Instead of incremental cost-effectiveness ratios, different options are compared using net monetary benefits. Net monetary benefit for each strategyis calculated as:

Willingness-to-pay threshold * Net quality-adjusted life expectancy – Net costs

At any given willingness-to-pay threshold, the option with the highest net monetary benefit is the “preferred” option. Given the uncertainty in model parameters, the preferred option may vary from simulation to simulation. The upper bound of the opportunity cost of making the wrong decision can be estimated by calculating the expected value of perfect information (EVPI), the difference between the expected outcome (measured as net monetary benefits) given the current uncertainty and the expected net benefit given perfect information.

For example, if we are comparing Treatment X and Treatment Y at a $50,000/quality-adjusted life year (QALY) threshold and perform five simulations, Treatment X might be optimal in three of the simulations, and Treatment Y in two (Table 1; this example is based on one given in Briggs, Schulpher, and Claxton [2006],9 p. 175).

Table 1 Example of expected value of information

Simulation number | Net benefits X | Net benefits Y | Preferred Option | Maximum benefit | Opportunity cost
1 | 20 | 30 | Y | 30 | 0
2 | 15 | 12 | X | 15 | 3
3 | 18 | 15 | X | 18 | 3
4 | 14 | 18 | Y | 18 | 0
5 | 17 | 14 | X | 17 | 3
Expected (average) value | 16.8 | 17.8 | | 19.6 | 1.8

The currently available information, when synthesized in the model, provides an expected net benefit for each option—this is the average of the individual net benefit calculated during each individual simulation. Because the average for Y (17.8) is higher than for X (16.8), we would choose Y, given the higher value. However, if we knew what the results were for each simulation, we would choose the option with the highest net benefit in that simulation. The average of the maximum values for the entire set of simulations is the expected value given perfect information (i.e., knowing in advance which outcome would be optimal). The difference between this value (19.6) and the expected value given current information (17.8) is the expected value of perfect information (1.8).

Alternatively, this can be conceptualized as the opportunity cost based on making the wrong decision. If we choose Treatment Y based on its higher expected value, there is a 60 percent chance that we would be wrong; the difference between the net benefits of Y and X in each simulation where X was preferred (numbers 2, 3, and 5 in Table 1) represents the opportunity cost of choosing Y based on its expected value; the expected overall opportunity cost is the average of these, or 1.8 (identical to the value obtained by subtracting the expected value given current information from the expected value given perfect information).

In this example, the reason that Treatment Y has a higher expected value is the outlier value of 30 obtained in the first simulation. Further research might result in a narrower range of parameter values for treatment Y, and thus an overall lower expected net benefit. The decision model generates estimates of the EVPI for individual patients; these can then be converted to a population-level estimate based on the number of potential patients, the time horizon under which the intervention will be used, and an appropriate discount rate. If the expected costs of research to reduce uncertainty are less than the population EVPI, then further research could be considered. At the simplest level, using the example above, the EVPI value of 1.8 would be multiplied by the expected number of patients over a given future time horizon, incorporating an appropriate discount rate; this value represents the upper bound of what would be reasonable to spend to reduce uncertainty surrounding Treatments X and Y. As a tool for research prioritization, the population EVPI has two potential applications: (a) as a “go/no go” threshold for deciding whether further research is worthwhile; and (b) in theory, as a way to compare the “cost-effectiveness” of research across different interventions, or even across different clinical problems or therapeutic areas.

The partial EVPI, or expected value of partial perfect information (EVPPI), is a further extension of this concept. In this case, the EVPPI for a specific variable or group of variables is estimated, usually by holding the value of that variable or group of variables constant and performing the rest of the probabilistic analyses; the results provide an estimate of the cost-effectiveness of reducing uncertainty for specific variables. In our example above, the impact of uncertainty in individual parameters (such as costs of side effects or patient adherence to treatment) on the optimal decision between Treatment X and Treatment Y would be estimated; those with higher EVPPIs would be considered of greater priority. These estimates have two potential applications in research prioritization: (a) identifying the variables of greatest importance in reducing uncertainty, and (b) allowing researchers to consider both the relative impact of specific variables on uncertainty and the relative costs of reducing that uncertainty. For example, estimates of the impact of varying degrees of precision for effectiveness estimates can be used in sample size calculations. Alternatively, the EVPPI analysis may show that reducing uncertainty surrounding variables that require less costly study designs may have almost as a big an impact on the optimal decision as variables requiring expensive and time-consuming prospective randomized trials. At the individual level, EVPPI functions as a form of sensitivity analysis5,6,10 and, at the population level, can provide budgetary guidance.

The Minnesota EPC team reviewed 11 evidence reports or CERs that involved modeling.2 Although the models were used for a variety of purposes, none of them was explicitly used as a tool to assist with research prioritization, even though the authors of several of the models noted that the usefulness of the models was limited by the lack of available evidence. The draft Minnesota report thoughtfully describes both the potential uses (including VOI) and challenges of incorporating models into systematic reviews. In this report, we focus specifically on the potential use and challenges of using models as tools to assist with research prioritization of the gaps identified by systematic reviews performed as part of the EPC program.

## Scope of Current Project

The overarching goal of this project, in concert with a suite of complementary projects conducted across several EPCs, is to inform the development of a set of methods recommendations for use by EPCs in drafting Future Research Needs sections of CERs coordinated by the AHRQ. The objective of this project in particular was to explore appropriate uses of modeling or VOI methods for developing and prioritizing research gaps from systematic reviews. We approached this aim by considering and compiling data from multiple sources. These approaches included:

- A systematic review of published literature regarding research priority setting, with a focus on the use of modeling and VOI;
- A review of priority-setting methods or strategies used by organizations involved in sponsoring research, again focusing on modeling and VOI; and
- Two case studies exploring the use of modeling and VOI methods in research priority setting. The case studies were chosen primarily out of convenience. Case Study 1 was chosen because of parallel modeling work on the topic done as part of a separate Future Research Needs project. Case Study 2 was chosen because the Duke EPC had previously written an Evidence Report on the topic incorporating a simulation model; investigators for that report were also involved in a separate, recently completed AHRQ-funded project to develop a research agenda for the topic using consensus-based methods, facilitating comparison of the results of a model-based process to a consensus-based one.

### Systematic Review

The systematic review component of the project focused on identification of published literature addressing methods of priority setting, including VOI. The articles of interest in this review were those presenting specific research prioritization recommendations. Although we extracted a range of information on research prioritization, we focus here on applications of modeling and VOI, particularly on the use of modeling and/or VOI as part of systematic reviews.

### Review of Individual Group Priority-Setting Processes

Priority-setting methods in practice at selected national and international research sponsoring agencies were reviewed through an assessment of publicly available information (published documents or information accessible from online sources) and contacts to individual organizations via e-mail or phone. These individual contacts offered organizations the opportunity to expand upon data available through print or online access with additional detail. Again, we focus here on aspects relevant to the potential use of VOI.

### Case Study 1: ACEIs/ARBs in Ischemic Heart Disease

In the first case study, we elaborated further on work published by the University of Connecticut EPC in a recent CER11 to identify and prioritize gaps in the evidence supporting the comparative effectiveness of angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin II receptor antagonist(s) (ARBs)in patients with ischemic heart disease (IHD). The prioritization process used in this case study combined a review of recently published and ongoing studies, development of a decision analytic model to explore engagement of a stakeholder group, and participation of these stakeholders in both qualitative and quantitative exercises, based on a sensitivity analysis approach, of research needs prioritization.

This case study was chosen to parallel work that the Duke EPC was performing for a pilot project on CER research prioritization. Although our investigative team had previously developed a decision model framework for the use of ACEIs and ARBs in essential hypertension patients, the framework and accompanying model was in the early stages of development. The structural modifications and evidence synthesis required for the translation of this model for the prioritization of research related to ACEIs and ARBs in IHD, and the broader goals of our pilot project, meant that we focused this first case study on the use of a decision analytic model and related sensitivity analyses and explored the more in-depth use of VOI analyses in our second case study described below.

### Case Study 2: Uterine Fibroids

The second case study for this project involved updating a Markov state-transition model initially developed for a prior evidence report on management of uterine fibroids.12 This case study also builds on a concurrent AHRQ-supported project titled “Research on the Comparative Management of Uterine Fibroid Disease” being conducted by the Outcome Developing Evidence to Inform Decisions about Effectiveness (DEcIDE) Center.1 The DEcIDE work employed a modified Delphi/nominal group methodology to prioritize research needs qualitatively in the uterine fibroids clinical area. Our update of the previously developed decision model was followed by VOI analyses to establish qualitatively based prioritization rankings for potential research areas identified as knowledge gaps. Stakeholders for this case study were drawn from the pool of technical experts involved in the Outcome DEcIDE work, thus allowing a direct comparison of the qualitative and quantitative approaches by a stakeholder group involved in both methods.