# Appendix F Detailed Description of Uterine Fibroids Model

## MODEL STRUCTURE

States: The model is a Markov state-transition model, which starts after performance of one of the three procedures of interest—myomectomy, uterine artery embolization (UAE), or MRI-guided focused ultrasound (FUS). Health states include:

- Immediate postprocedure, no complications
- Immediate postprocedure, complications
  ○ Both of these states can transition into improved, persistent, or recurrent symptoms
- Improved symptoms
  ○ Women who desire pregnancy can transition into Attempting Pregnancy, or into Recurrent Symptoms. We assume that only women experiencing improved symptoms will attempt pregnancy.
- Persistent symptoms
- Recurrent symptoms
  ○ We assume all of these women eventually transition into the Retreatment state.
- Attempting Pregnancy
  ○ These women either become pregnant, seek infertility treatment after an age-dependent period of time without conception, or develop recurrent symptoms.
- Pregnant
  ○ These women can experience a miscarriage, deliver a preterm infant, or deliver a term infant.
- Retreatment
- Miscarriage
- Preterm delivery
- Term delivery
- Infertile
  ○ For the purposes of this modeling exercise, the above five states are “absorbing” states—we do not continue to model events after these occur. Although doing so would be of great interest, incorporating them would have added even more complexity to an already complex model, especially given the methodologic issues involved with modeling events such as preterm birth which affect more than one individual.

We did not include mortality, either from other causes or from the procedure itself. All-cause mortality is quite low in this age group. Reliable estimates for mortality associated with individual procedures are difficult to obtain from readily available sources—there are no count data on in-hospital deaths for myomectomy or UAE for women 15–44 within HCUP, and estimates based on hysterectomy are likely to overestimate mortality risk, especially if all-indication rates are used.

We did not include long-term complications from any of the procedures, because of both a relative paucity of long-term data and a desire to focus on other understudied aspects of treatment.

We also did not include menopause, or any potential effects of treatment on ovarian function. We believe this is an area of great importance and one for which models may useful; however, the further complexity of modeling ovarian function and its effects on fibroid symptoms, menopausal symptoms, and fertility, as well as the potential effects of different treatments on ovarian function, was beyond the scope of this project.

Cycle length: We used 1-week cycle lengths. This length allowed us to more precisely model short-term postprocedure outcomes (although days would obviously be preferable), and, more importantly, made it much easier to model time-dependent reproductive outcomes, which are usually reported in either weeks or cycles of approximately 4 weeks duration.

Time horizon: We modeled a 3-year time horizon, primarily because of limited data on outcomes beyond 3 years. Exploring the impact of possible longer-term differences in treatment outcomes is an important next step.

Discount: We discounted costs and quality-adjusted life expectancy at a 3 percent annual rate, varied from 0–5 percent in sensitivity analysis.

Software: The model was built and run in TreeAge Pro 2009 (Williamstown, MA: TreeAge, Inc). Microsoft Excel was used for deriving conditional probabilities from published cumulative probability data.

## PATIENT DEMOGRAPHICS

Racial distribution: In the base case, we assumed that 48 percent of the population would be African-American, consistent with the baseline patient demographics in the FIBROID UAE registry.1 Because 85–95 percent of patients in those studies that report racial/ethnic distributions are either African-American or white, and because racial differences in pregnancy outcomes are most well-characterized for African-Americans versus whites, we did not separately model either age or reproductive outcomes for other ethnic groups.

Interest in pregnancy: At the baseline visit in the FIBROID registry, approximately 25 percent of women expressed a desire to retain the potential for future childbearing, with 9 percent expressing definite plans within the next 2 years. Because there are no published data on racial differences among women seeking fibroid treatment who wish to attempt pregnancy after treatment, we assumed equal proportions among racial groups (although the higher parity among African-American women suggests that this is worthy of further exploration).

Data on age distribution among women desiring the potential for pregnancy versus those who don’t are not readily available, although it seems likely that these women would be younger. We describe our methods for our age distribution assumptions for this subgroup in the next section.

Age: Among women presenting with fibroids, African-American women are consistently younger than white women for any given procedure; for example, mean age of African-American women in the FIBROID registry was 42.5 years, versus 44.5 for white women. Women undergoing myomectomy are also younger than women undergoing UAE (38.2 vs. 43.9 in one prospective series2); this is at least partially due to current guidelines considering desire for pregnancy a relative contraindication for UAE. The published age distribution of women undergoing focused ultrasound is comparable to that of women undergoing UAE, again in part because the majority of these studies excluded women planning further childbearing. Studies that report summary statistics for age typically report means and standard deviations; for the purposes of this model, we assume normal distributions for each age group, although other distributions are also plausible (for example, a left skew for women wanting pregnancy and a right skew for women who definitely have completed childbearing).

Taking the above into account, we modeled age as follows:

- We restricted the age range from 25–44 years, to (a) incorporate the group with realistic probabilities of pregnancy, and (b) to reduce the potential interaction of natural perimenopausal changes with treatment effects on outcomes. This is clearly an area for further model development.
- We assumed a mean age of 40.0 years to better reflect women who would be potential candidates for any of the procedures.
- We assumed a 2-year difference in mean age between African-American and white women (39.0 and 41.0).
- Given that 25 percent of women desire future pregnancy, the mean age of this group among African-American women would be 34.5 years, and among white women 36.5 years.
- Mean age for the 75 percent of African-American women not desiring pregnancy would be 39.5 years, and 41.5 years for white women not desiring pregnancy.
- In order to obtain an age distribution which would reflect our restricted range of 25–44, we performed simulations and varied the standard deviations. A SD of 2.5 resulted in over 99 percent of the youngest group (African-American women desiring pregnancy) with an age 25 and older, and over 90 percent of the oldest group (white women not desiring pregnancy) with an age less than 45.

Uterine anatomy: There are fairly consistent data that the number, size, and location of fibroids can affect the likelihood of different outcomes. Due to resource constraints, we did not incorporate baseline uterine anatomy into the model, but this would be an interesting next step.

Other patient characteristics: We did not include other patient characteristics that have been reported to affect outcomes, such as BMI or history of previous surgery.

### REPRODUCTIVE OUTCOMES

Time after procedure: There is a lack of consensus on recommended times after myomectomy for attempting conception, as well as a lack of data for myomectomy, UAE, or FUS on the distribution of time after procedure before women attempt pregnancy. Based on our clinical experience and reviewing several Internet chat boards for women with fibroids, we believe most clinicians would recommend 3–6 months; we therefore assumed a mean time of 5 months, with a standard deviation of 1 month.

Time to attempt pregnancy before seeking infertility care: We assumed women under the age of 35 would seek infertility care after 12 months without a pregnancy, while women 35 and older would seek care after 6 months, based on current guidelines from the American Society for Reproductive Medicine.

Pregnancy rates: Fertility is highly dependent on maternal age. Because data on relative age-specific fertility rates between African-American and white women are lacking, we modeled only age dependency for fertility.

We took data from several sources—studies of couples undergoing donor insemination for azoospermia3,4 and 2008 data from CDC on cycle-specific pregnancy rates after undergoing assisted reproductive technology (ART) with fresh embryos from nondonor eggs (http://www.cdc.gov/art/ARTReports.htm). Because the CDC data reflect couples undergoing ART, we reduced the age-specific rates across all ages to result in cycle specific rates which, when converted to 12-month cumulative rates, resulted in values similar to that observed in the other studies for younger women (a reduction of approximately two-thirds).

We plotted age versus monthly pregnancy in Excel, and generated curves to fit the observed data (Figure F1). For both the insemination data and adjusted CDC data, the fitted curves had R^2^ values above 0.99. Because the decline in fecundity is especially rapid after age 35, we used these formulae to generate age-specific pregnancy probabilities rather than tables coded to an individual year. Because the estimated 12-month rate in older women was substantially higher in the adjusted ART data than in the insemination studies, we used the more conservative estimates.

Figure F1 Age versus monthly pregnancy

Conception can only occur when intercourse takes place during a 6-day window ending at ovulation.5 Because the cycle length in the model is 1 week, we assumed a 28-day cycle, and that the probability of pregnancy would be 0 for weeks 1, 3, and 4, and the age-specific fertility rate during week 2.

Spontaneous abortion rates: Spontaneous abortion rates are also highly dependent on maternal age (as with pregnancy rates, we assumed that age-specific rates would be similar for African-American and white women). We derived age-specific spontaneous miscarriage rates for clinical pregnancies (pregnancy detected at 5–6 weeks gestation) for weeks 6 through 20 from two sources. First, we used gestational age-specific loss rates from a large prospective cohort study of women attempting to get pregnant6 to generate conditional probabilities of spontaneous abortion for each week. We then adjusted these weekly rates to fit age-specific cumulative loss rates from a population-based study.7 As with the fecundity data, we fitted an equation to the observed data to generate age-specific estimates in 1-year increments.

Figure F2 shows the estimated cumulative loss rates between 6 and 20 weeks, stratified by maternal age, for ages 25, 30, 35, 40, and 44.

Figure F2 Estimated cumulative loss rates between 6 and 20 weeks, stratified by maternal age

Gestational age-specific delivery rates: We used the most recently available (2006) birth certificate data from the National Center for Health Statistics (http://www.cdc.gov/nchs/data_access/vitalstats/VitalStats_Births.htm) to generate tables of number of deliveries between 20 and 42 weeks, stratified by best estimated gestational age (in weeks), maternal age (in years), and racial group (African-American vs. white). Because the standard of care in the United States is to deliver all ongoing pregnancies between 42–43 weeks because of an increased risk of stillbirth, we included the small number of deliveries estimated as beyond 42 weeks in the 42-week total.

We then used these tables to generate the conditional probability of delivery for each week of pregnancy, again stratified by maternal age and race (Figure F3).

Figure F3 Conditional probability of delivery per week of pregnancy, stratified by maternal age and race

NOTE: We did not further stratify delivery probability by parity, primarily because the available literature did not provide sufficient detail to include parity and age and race without making further assumptions. Women seeking fibroid treatment who are considering childbearing are more likely to be nulliparous or have low parity. Because nulliparous women are at higher risk for a variety of adverse outcomes (including preterm birth), accounting for differences in parity would further refine the model’s ability to estimate adverse reproductive outcomes. We also did not include other pregnancy outcomes that have been associated with fibroids or fibroid treatments.

Impact of fibroids on reproductive outcomes: Two recent meta-analyses found significant effects of fibroids on clinical pregnancy rates, spontaneous abortion rates, and preterm birth rates, with some variation in risk depending on fibroid location.8,9 For the purposes of the model, we used the estimates from each review that included all fibroids rather than site-specific risks—future refinement of the model could stratify risk by fibroid location at baseline (Table F1).

Table F1 Effects of fibroids on clinical pregnancy, spontaneous abortion, and preterm birth rates

Outcome | OR | 95% CI | Reference
Clinical pregnancy | 0.85 | 0.734, 0.983 | 8
Spontaneous abortion | 1.68 | 1.37, 2.05 | 8
Preterm birth | 1.5 | 1.3, 1.7 | 9

OR = odds ratio; CI = confidence interval

Modeling the impact of fibroids and fibroid treatments on these outcomes is difficult for a variety of reasons beyond the methodological issues involved in the primary studies themselves. From the standpoint of appropriate parameter derivation, the primary issue is that overall population event rates represent the weighted average of the rates in people with a given risk factor and in those without the risk factor. Given the overall event rate, the relative risk associated with a given factor, and the prevalence of the factor in the population, the individual rates can be easily derived. If this correction is not done, simply multiplying the population rate by the relative risk associated with the risk factor will result in an overestimation of both the overall risk and the risk in people with the risk factor. Another issue is that the available data, both in individual studies and systematic reviews, are summarized as relative risks or odds ratios; for the purposes of our model, which uses time-dependent conditional probabilities, hazard ratios would be more appropriate.

In the case of reproductive outcomes associated with fibroids, some of the overall population rates are likely due to fibroids, but data on the prevalence of asymptomatic fibroids in the appropriate populations are lacking, particularly in the general population of women seeking to achieve pregnancy. For the impact of fibroids on fertility, we assumed no impact on overall age-specific fecundity in the base case, but varied the relative risk to 0.85 (i.e., a 15% reduction in age-specific cycle fecundity). We used the observed prevalence of fibroids in a large prospective study of early pregnancy10 as the assumed population prevalence; however, if fibroids do adversely affect the probability of a detectable clinical pregnancy, than the observed prevalence in women in early pregnancy will be lower than in the overall population of women trying to conceive.

We used the prevalence of fibroids reported in Laughlin et al.10 and adjusted the weekly probability of spontaneous abortion and delivery under 37 weeks accordingly, using the summary relative risks reported by Klatsky et al.9

## TREATMENT OUTCOMES

Short-term complications: Because we modeled costs and return to work separately for patients with and without complications, we focused solely on major short-term complications. The largest series with detailed reporting was the FIBROID registry,11 with a major complication rate of 0.66 percent. We modeled the probability of major complications with the other procedures as relative risks, using 2.0 in the base case for myomectomy,2 and 0.01 for FUS (assumption).

Long-term complications: We did not model post-discharge complications, either within the “typical” recovery time or over the course of the simulation. Although differential complications rates will have some impact on both costs and quality-of-life outcomes, most studies did not report data in great detail. Because the impact of periprocedural complications, including ones within the first 30–45 days of the procedure, would translate into differences in the distribution of costs and return to activity, we varied short-term complication rates, which have the effect of increasing the overall mean periprocedural costs and time lost from usual activities, as a surrogate.

Relief of symptoms: Following other recent cost-effectiveness analyses of fibroid treatments, we used retreatment as a surrogate marker for recurrent symptoms. We identified studies that reported at least 24-month data on cumulative retreatment rates (Table F2).

Table F2 Studies reporting at least 24-month data on cumulative retreatment rates

Time | UAE | | | Myomectomy | | | FUS12
Time | EMMY13 | FIBROID14 | HOPEFUL15 | REST16 | Hanafi17 | Subramanian18 | All Subjects | % nonperfused
Time | EMMY13 | FIBROID14 | HOPEFUL15 | REST16 | Hanafi17 | Subramanian18 | All Subjects | <20 | 20+
3 | 0.075
6 | 0.102 | 0.025 | | | | 0.083 | 0.031 | 0.04 | 0.02
9 | 0.129
12 | 0.172 | 0.055 | 0.074 | 0.094 | 0.01 | 0.106 | 0.236 | 0.3 | 0.15
15 | 0.231
18 | 0.263
21 | 0.279
24 | 0.295 | 0.098 | 0.116 | 0.198 | 0.03 | 0.183 | 0.336 | 0.4 | 0.25
27 | 0.311
30
33
36 | 0.329 | 0.138 | 0.145 | | 0.1

EMMY = EMbolization versus hysterectoMY trial; FIBROID = FIBROID registry; FUS = MRI-guided focused ultrasound; HOPEFUL = Hysterectomy Or Percutaneous Embolisation for Uterine Leiomyomata study; REST = Randomised Study of Embolisation and Surgical Treatment for Uterine Fibroids; UAE = uterine artery embolization

[underlined: Persistent symptoms:] We assumed that all retreatments in the first 6 months after the initial treatment represented persistent symptoms. We used the rates from Subramanian for myomectomy, and Stewart et al for FUS. In the case of FUS, we used the rates for higher treatment volumes to reflect current clinical practice. Because the EMMY trial rates were substantially higher than any of the others for longer term outcomes, we elected to use the 6 month rate from the FIBROID registry as the base case. We used the lowest reported rate (UAE) as the reference, and modeled rates for myomectomy and FUS as relative rates.

[underlined: Recurrent Symptoms:] We recalculated the cumulative retreatment rates after removing those who “persisted” within 6 months from the at-risk pool. We also assumed that symptoms would recur on average 3 months prior to retreatment. We used the U.S.-based FIBROID and UK-based HOPEFUL studies for deriving rates for UAE, and the Subramanian and Stewart studies for myomectomy and FUS (Figure F4). After plotting the observed rates, curves were fitted to the cumulative probabilities, all with R^2^ values above 0.99. These functions were then used to calculate conditional probabilities (Figure F5).

Figure F4 Recalculated cumulative probabilities of recurrence after removal of “persistent” cases and assumption of recurrence occurring 3 months prior to retreatment (symbols) and fitted curves to observed data (lines)

FIBROID = FIBROID registry; HOPEFUL= Hysterectomy Or Percutaneous Embolisation for Uterine Leiomyomata study;, Myo = Subramanian; FUS = Stewart

Figure F5 Plot of conditional probabilities of recurrence derived from fitted cumulative

FIBROID = FIBROID registry; HOPEFUL= Hysterectomy Or Percutaneous Embolisation for Uterine Leiomyomata study;, Myo = Subramanian; FUS = Stewart

On the basis of these studies, recurrence risk fits a proportional hazards model, which is especially helpful for modeling comparative effectiveness, since the relative effectiveness of a given treatment can be modeled using hazard ratios. We chose the FIBROID registry data as the reference (and modeled the variability in observed recurrence rates using hazard ratios), and varied hazard ratios for myomectomy and FUS across a wide range, from 0.85 to 3.0. In the base case, we used a HR of 1.1 for myomectomy and 3.0 for FUS.

NOTE: We did not incorporate the potential effect of patient characteristics on recurrence rates. In particular, age is consistently a predictor of recurrence risk for UAE, and likely for other treatments as well. Incorporating age-specific effects is an important next step, but requires additional data (such as specific parameters from survival analyses from primary studies).

Impact on reproductive function: There are no large-scale data on comparative impact of different treatments on reproductive function. We therefore modeled the potential impact of each treatment by adjusting the relative risk associated with fibroids on fertility, miscarriage, and preterm birth. A fully effective treatment would reduce this relative risk to 1.0 (so that the rate would be equivalent to women of the same age and racial group without fibroids); we included the possibility of treatments reducing fertility or increasing the risk of miscarriage or preterm birth.

## COSTS

Procedure costs: Using the Nationwide Inpatient Sample from the Healthcare Cost and Utilization Project, we identified hospital admissions in 2008 with diagnoses of uterine fibroids (ICD-9 218.0–218.9) and procedure codes for myomectomy (ICD-9 68.29) or uterine artery embolization (ICD-9 99.29). The estimated mean and median charge data from HCUP were converted to costs assuming a 0.6 cost/charge ratio. These were then inflated to 2010 data using the medical care component of the Consumer Price Index (www.bls.gov).

Using the adjusted mean and medians, we generated lognormal distributions for hospital costs and generated a distribution using 10,000 simulations. We assumed that the right tail represented patients with periprocedural complications. We generated separate estimates for uncomplicated and complicated procedures as follows:

- For uncomplicated procedures, we took the interquartile range from the overall lognormal distribution and calculated the mean and standard deviation.
- For complicated procedures, we took the upper quartile, calculated mean and medians, and generated a new lognormal distribution.

We did not identify similar population-based data for focused ultrasound. To estimate costs, we took the mean cost from a previously cost-effectiveness analysis, which were derived from the Medstat database (REF) and inflated it to 2010 dollars. The estimated costs used in this study for myomectomy and UAE were somewhat lower than those derived from HCUP data, likely reflecting a somewhat different patient population (privately insured patients) with a different overall spectrum of disease and comorbidities. Since the populations undergoing UAE and focused ultrasound to date are more similar than the populations undergoing either procedure to those undergoing myomectomy, we adjusted the reported Medstat costs for focused ultrasound by the same ratio as that used in the previous analysis. We assumed that the ratio of median to mean costs would be similar to that observed for myomectomy and UAE (approximately 0.85), and used a similar approach to generate estimates for complicated and uncomplicated cases (Table F3).

Table F3 Estimated costs for fibroid treatment with myomectomy, UAE, and focused ultrasound

| Myomectomy | | | | UAE | | | | Focused ultrasound
Medstat cost estimate^*^ | $10,5461 | | | | $12,688 | | | | $8,028
HCUP cost estimate^*^ | Mean | | Median | | Mean | | Median | | Mean | | Median
HCUP cost estimate^*^ | $14,775 | | $12,885 | | $15,375 | | $13,091 | | NA | | NA
Derived cost estimates^*^ | No comp | Comp | No comp | Comp | No comp | Comp | No comp | Comp | No comp | Comp | No comp | Comp
Derived cost estimates^*^ | 13043 | 25699 | 12737 | 23410 | 13359 | 28025 | 13072 | 25149 | 9917 | 20805 | 9713 | 18542

HCUP = Healthcare Cost and Utilization Project; NA = not applicable; UAE = UAE = uterine artery embolization

* 2010 USD

There is no ideal data set for estimating costs associated with fibroids, because of differences in patient characteristics which could affect outcome, different coverage levels, and different sites of care (for example, the Nationwide Inpatient Sample does not capture procedures performed on an outpatient basis).

Productivity costs: Data on estimated annual incomes by age and race for women were obtained from the 2009 Annual Social and Economic Supplement to the Current Population Survey (www.census.gov) and reflect 2008 data; these were inflated to 2010 values using the Employment Cost Index (www.bls.gov) (Table F4). Age- and race-specific wages were modeled as lognormal distributions. Annual wages were converted to daily values for estimating the impact of treatment and symptoms on productivity.

Table F4 Estimated annual incomes for women by age and race

Age | White | | African-American
Age | Mean | Median | Mean | Median
25–29 | $27,853 | $25,138 | $24,216 | $20,564
30–34 | $32,019 | $26,645 | $29,007 | $24,971
35–39 | $36,281 | $27,413 | $32,651 | $28,735
40–44 | $35,424 | $27,161 | $31,598 | $26,112

We derived recovery times as follows:

- Data on mean and median lengths of stay for myomectomy and UAE were obtained from HCUP. Using an approach similar to the one we took for deriving costs for uncomplicated and complicated cases, we generated distributions for length of stay.
- Some data on mean times for return to work and return to usual activities are available for myomectomy and UAE,2 and for FUS,19 although there are no data on the distribution of these times (although the data on FUS are strongly suggestive of a non-normal distribution). For simplicity, we used a normal distribution with a small standard deviation (1–2 days), under the assumption that most of the variability in time to return to work or usual activities after the procedure would be driven by complications and length of hospital stay (Table F5).

Table F5 Recovery times for myomectomy, UAE, and FUS

| Myomectomy | | UAE | | FUS
LOS (days) (HCUP) | Mean | Median | Mean | Median | Mean | Median
LOS (days) (HCUP) | 2.4 | 2.0 | 1.4 | 1.0 | -- | --
Return to usual activities or work (days) | 14.6 (usual activities) 9.9 (work) 2 | -- | 44.4 (usual activities) 37.0 (work)2 | -- | 1.2 ± 2.3 (usual activities) 0.8 ± 0.5 (work)19
Derived added time after hospital discharge before return to usual activities | 12.0 ± 1.0 days | | 43.0 ± 2.0 days | | 0

FUS = MRI-guided focused ultrasound; HCUP = Healthcare Cost and Utilization Project; LOS = length of stay; UAE = uterine artery embolization

Productivity losses were modeled based on assumptions about missing work; we did not model decreases in productivity in symptomatic women who were able to be present at work.

Retreatment costs: We used the overall mean and median costs (which include both complicated and uncomplicated cases) for UAE, myomectomy, and FUS for retreatment costs, modeled as lognormal distributions. We also included the possibility of hysterectomy as a retreatment, and used mean and median charges, converted to costs using a 0.6 cost/charge ratio and inflated to 2010 USD, from the 2008 Nationwide Inpatient Sample. We did include varying costs based on a possible higher risk of complications in repeat procedures, although this would be straightforward to include.

Pregnancy-related costs: We did not include the costs of routine prenatal care, management of miscarriage or preterm labor, or fertility evaluation. We did include the mean costs of a preterm infant, inflated to 2010 USD20 ($61,209). The model also has the capability of more precisely estimating the impact of preterm birth by using gestational age-specific morbidity and mortality rates.

We did not include several other potentially relevant costs, including:

- Transportation and child care costs
- Costs for office visits, prescription or over-the-counter medications, and supplies (such as sanitary products) for patients with persistent or recurrent symptoms

## UTILITIES

Utilities, which are used to weight the duration of time spent in a given health state according to that state’s relative impact on quality of life, range from 0 (death) to 1.0 (perfect health). Utilities used in previous studies are quite variable (Table F6).

Table F6 Utilities used in previous studies

STATE | STUDY
STATE | Kuppermann21 | Hirst15 | Zowall 22 | O’Sullivan 23
Symptomatic fibroids | 0.80 ± 0.01 (bleeding) 0.88 ± 0.01 (pressure) | 0.705 | -- | 0.67
Recovery from procedure | -- | -- | 0.757 (myo) 0.783 (UAE) 0.783 (FUS)
Symptom relief | -- | 0.825 | 0.802 | 0.76
Sources for utility value | Primary data collection using time tradeoff among symptomatic patients | Derived from SF-36 scores in REST trial | Derived from previous CEA of endometrial ablation | Unpublished data—unclear whether from utility scores or derived from other scale

As with many of the other parameters, we elected to model utilities as relative functions, using absolute changes. We used 0.70 as the baseline utility for symptomatic fibroids, and assumed that persistent and recurrent symptoms would have the same utility. We assumed that improved symptoms would lead to a mean increase of 0.12 in utility scores, with a standard deviation of 0.01 (although utilities are rarely normally distributed, we elected to model them as a normal distribution in the absence of any reliable data for using alternative distributions). Utilities during recovery are 60 percent (myomectomy) and 80 percent (UAE, FUS) of the final improved utility.

There are almost no data on utilities relevant to reproductive outcomes. The data that are available suggest that infertility is likely to have a lower value among nulliparous women than other outcomes. For example, in a study in U.K. women awaiting in vitro fertilization, the only outcome with a lower utility score using the standard gamble than continued infertility was an infant death followed by permanent infertility; 85 percent rated having a child with a permanent physical impairment equal or worse than infertility, 94 percent rated a child with a permanent cognitive impairment equal or worse, and 96 percent rated a child with permanent visual impairment equal or worse.24 Median (IQR) score for infertility was 0.815 (0.712–0.977), with scores for physical, cognitive, or visual impairment, or preterm birth (the proximate cause of the impairments) as 0.94–0.97. This is consistent with U.S. studies of infertility patients,25 as well as parental utility scores for other infant/childhood outcomes.26,27 In another U.S. study of utilities for states relevant to pelvic inflammatory disease, infertility had a mean score of 0.84 with a median of 1 and IQR of 0.81–1 among 150 women with no history of PID, 65 percent of whom desired or planned to get pregnant in the future.

Based on these results, we assumed that women attempting pregnancy would maintain the “Improved Symptoms” utility of 0.12, with no change with a pregnancy resulting in a live birth. A diagnosis of infertility would result in a 0.06 reduction in utility, with the range varied from 0.06 to 0.12 (i.e., infertility equivalent to symptomatic fibroids).

## REFERENCES

1 Myers ER, Goodwin S, Landow W, et al. (2005). Prospective data collection of a new procedure by a specialty society: the FIBROID registry. Obstet Gynecol.
2 Goodwin SC, Bradley LD, Lipman JC, et al. (2006). Uterine artery embolization versus myomectomy: a multicenter comparative study. Fertil Steril.
3 Schwartz D, Mayaux MJ. (1982). Female fecundity as a function of age: results of artificial insemination in 2193 nulliparous women with azoospermic husbands. Federation CECOS. N Engl J Med.
4 van Noord-Zaadstra BM, Looman CW, Alsbach H, et al. (1991). Delaying childbearing: effect of age on fecundity and outcome of pregnancy. BMJ.
5 Wilcox AJ, Weinberg CR, Baird DD. (1995). Timing of sexual intercourse in relation to ovulation. Effects on the probability of conception, survival of the pregnancy, and sex of the baby. N Engl J Med.
6 Hasan R, Baird DD, Herring AH, et al. (2010). Patterns and predictors of vaginal bleeding in the first trimester of pregnancy. Ann Epidemiol.
7 Nybo Andersen AM, Wohlfahrt J, Christens P, et al. (2000). Maternal age and fetal loss: population based register linkage study. BMJ.
8 Pritts EA, Parker WH, Olive DL. (2009). Fibroids and infertility: an updated systematic review of the evidence. Fertil Steril.
9 Klatsky PC, Tran ND, Caughey AB, et al. (2008). Fibroids and reproductive outcomes: a systematic literature review from conception to delivery. Am J Obstet Gynecol.
10 Laughlin SK, Baird DD, Savitz DA, et al. (2009). Prevalence of uterine leiomyomas in the first trimester of pregnancy: an ultrasound-screening study. Obstet Gynecol.
11 Worthington-Kirsch R, Spies JB, Myers ER, et al. (2005). The Fibroid Registry for outcomes data (FIBROID) for uterine embolization: short-term outcomes. Obstet Gynecol.
12 Stewart EA, Gostout B, Rabinovici J, et al. (2007). Sustained relief of leiomyoma symptoms by using focused ultrasound surgery. Obstet Gynecol.
13 van der Kooij SM, Hehenkamp WJ, Volkers NA, et al. (2010). Uterine artery embolization vs hysterectomy in the treatment of symptomatic uterine fibroids: 5-year outcome from the randomized EMMY trial. Am J Obstet Gynecol.
14 Goodwin SC, Spies JB, Worthington-Kirsch R, et al. (2008). Uterine artery embolization for treatment of leiomyomata: long-term outcomes from the FIBROID Registry. Obstet Gynecol.
15 Hirst A, Dutton S, Wu O, et al. (2008). A multi-centre retrospective cohort study comparing the efficacy, safety and cost-effectiveness of hysterectomy and uterine artery embolisation for the treatment of symptomatic uterine fibroids. The HOPEFUL study. Health Technol Assess.
16 Edwards RD, Moss JG, Lumsden MA, et al. (2007). Uterine-artery embolization versus surgery for symptomatic uterine fibroids. N Engl J Med.
17 Hanafi M. (2005). Predictors of leiomyoma recurrence after myomectomy. Obstet Gynecol.
18 Subramanian S, Clark MA, Isaacson K. (2001). Outcome and resource use associated with myomectomy. Obstet Gynecol.
19 Stewart EA, Rabinovici J, Tempany CM, et al. (2006). Clinical outcomes of focused ultrasound surgery for the treatment of uterine fibroids. Fertil Steril.
20 (2007). Behrman RE, Butler AS, editors. Preterm birth: causes, consequences, and prevention.
21 Kuppermann M, Learman LA, Schembri M, et al. (2007). Effect of noncancerous pelvic problems on health-related quality of life and sexual functioning. Obstet Gynecol.
22 Zowall H, Cairns JA, Brewer C, et al. (2008). Cost-effectiveness of magnetic resonance-guided focused ultrasound surgery for treatment of uterine fibroids. BJOG.
23 O'Sullivan AK, Thompson D, Chu P, et al. (2009). Cost-effectiveness of magnetic resonance guided focused ultrasound for the treatment of uterine fibroids. Int J Technol Assess Health Care.
24 Scotland GS, McNamee P, Peddie VL, et al. (2007). Safety versus success in elective single embryo transfer: women's preferences for outcomes of in vitro fertilisation. BJOG.
25 Ryan GL, Zhang SH, Dokras A, et al. (2004). The desire of infertile patients for multiple births. Fertil Steril.
26 Carroll AE, Downs SM. (2009). Improving decision analyses: parent preferences (utility values) for pediatric health outcomes. J Pediatr.
27 Madsen KA, Bennett JE, Downs SM. (2006). The role of parental preferences in the management of fever without source among 3- to 36-month-old children: a decision analysis. Pediatrics.