# Appendix E Results of Prioritization Exercises—ACEI/ARB Case Study

## Results of Prioritization Exercise 1

Table D1 Importance of individual research areas (Prioritization Exercise 1, Likert scale)

Research area | Not at all important (1) | Somewhat unimportant (2) | Neutral (3) | Somewhat important (4) | Very important (5) | Average
Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multivessel coronary artery disease) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 14.3% (1) | 85.7% (6) | 4.86
The impact of ACE-I/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence | 0.0% (0) | 0.0% (0) | 14.3% (1) | 28.6% (2) | 57.1% (4) | 4.43
The impact of ACE-I/ARB in patients with stable IHD on utilization and cost of therapy | 0.0% (0) | 0.0% (0) | 0.0% (0) | 57.1% (4) | 42.9% (3) | 4.43
Impact of demographic differences (such as age, race, sex) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 71.4% (5) | 28.6% (2) | 4.29
Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 14.3% (1) | 42.9% (3) | 42.9% (3) | 4.29
The benefit of ACE-Is/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 14.3% (1) | 42.9% (3) | 42.9% (3) | 4.29
Strategies to enhance greater evidence-based use of ACE-Is/ARBs | 0.0% (0) | 0.0% (0) | 14.3% (1) | 42.9% (3) | 42.9% (3) | 4.29
The impact of ACE-I/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, non-fatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.) | 14.3% (1) | 0.0% (0) | 0.0% (0) | 14.3% (1) | 71.4% (5) | 4.29
The impact of ACE-I/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) | 0.0% (0) | 0.0% (0) | 14.3% (1) | 42.9% (3) | 42.9% (3) | 4.29
Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 85.7% (6) | 14.3% (1) | 4.14
The impact of ACE-I/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 28.6% (2) | 28.6% (2) | 42.9% (3) | 4.14
The impact of ACE-I/ARB in patients with stable IHD on patient quality of life | 0.0% (0) | 0.0% (0) | 28.6% (2) | 28.6% (2) | 42.9% (3) | 4.14
Impact of the dose response (impact of medication dose or dosing interval) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 28.6% (2) | 57.1% (4) | 14.3% (1) | 3.86
Impact of class effect (impact of differences between specific agents within each class) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD | 0.0% (0) | 14.3% (1) | 14.3% (1) | 42.9% (3) | 28.6% (2) | 3.86
The impact of ACE-I/ARB in patients with stable IHD on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) | 0.0% (0) | 0.0% (0) | 14.3% (1) | 85.7% (6) | 0.0% (0) | 3.86
The impact of ACE-I/ARB in patients with stable IHD on development of angioedema | 0.0% (0) | 0.0% (0) | 28.6% (2) | 71.4% (5) | 0.0% (0) | 3.71

ACE-I(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; CVA = cerebrovascular accident; IHD = ischemic heart disease; LV = left ventricular; MI = myocardial infarction; PICO = population, interventions, comparators of interest, and outcomes

Table D2 Ranking of research priorities using average Likert scale score

Rank | Research area
1 | Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi- vessel coronary artery disease) on ACE-I/ARB effectiveness or harms in patients with stable IHD
2 | The impact of ACE-I/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence
2 | The impact of ACE-I/ARB in patients with stable IHD on utilization and cost of therapy
3 | Impact of demographic differences (such as age, race, sex) on ACE-I/ARB effectiveness or harms in patients with stable IHD
3 | Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACE-I/ARB effectiveness or harms in patients with stable IHD
3 | The benefit of ACE-Is/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD
3 | Strategies to enhance greater evidence-based use of ACE-Is/ARBs
3 | The impact of ACE-I/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, non-fatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.)
3 | The impact of ACE-I/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function)
4 | Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE- I/ARB effectiveness or harms in patients with stable IHD
4 | The impact of ACE-I/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD
4 | The impact of ACE-I/ARB in patients with stable IHD on patient quality of life
5 | Impact of the dose response (impact of medication dose or dosing interval) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
5 | Impact of class effect (impact of differences between specific agents within each class) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
5 | The impact of ACE-I/ARB in patients with stable IHD on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia)
6 | The impact of ACE-I/ARB in patients with stable IHD on development of angioedema

ACE-I(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; CVA = cerebrovascular accident; IHD = ischemic heart disease; LV = left ventricular; MI = myocardial infarction; PICO = population, interventions, comparators of interest, and outcomes

Table D3 Ranking of importance of research areas (Prioritization Exercise 1, top five ranking)

Research area | 1 | 2 | 3 | 4 | 5 | Average
The impact of ACE-I/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.) | 75.0% (3) | 25.0% (1) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 4.75
The impact of ACE-I/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) | 0.0% (0) | 75.0% (3) | 25.0% (1) | 0.0% (0) | 0.0% (0) | 3.75
The benefit of ACE-Is/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD | 50.0% (1) | 0.0% (0) | 0.0% (0) | 50.0% (1) | 0.0% (0) | 3.5
Strategies to enhance greater evidence-based use of ACE-Is/ARBs | 50.0% (2) | 0.0% (0) | 25.0% (1) | 0.0% (0) | 25.0% (1) | 3.5
Impact of demographic differences (such as age, race, sex) on ACE- I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 50.0% (1) | 0.0% (0) | 50.0% (1) | 0.0% (0) | 3
The impact of ACE-I/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD | 25.0% (1) | 25.0% (1) | 0.0% (0) | 25.0% (1) | 25.0% (1) | 3
The impact of ACE-I/ARB in patients with stable IHD on patient quality of life | 0.0% (0) | 0.0% (0) | 100.0% (1) | 0.0% (0) | 0.0% (0) | 3
Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multivessel coronary artery disease) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 75.0% (3) | 25.0% (1) | 0.0% (0) | 2.75
Impact of class effect (impact of differences between specific agents within each class) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD | 0.0% (0) | 25.0% (1) | 25.0% (1) | 0.0% (0) | 50.0% (2) | 2.25
Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 100.0% (1) | 0.0% (0) | 2
The impact of ACE-I/ARB in patients with stable IHD on utilization and cost of therapy | 0.0% (0) | 0.0% (0) | 0.0% (0) | 100.0% (1) | 0.0% (0) | 2
Impact of concurrent medications (such as antiplatelet agents, lipid- lowering medications, other antihypertensives) on ACE-I/ARB effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 50.0% (1) | 50.0% (1) | 1.5
The impact of ACE-I/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 100.0% (2) | 1
Impact of the dose response (impact of medication dose or dosing interval) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0
The impact of ACE-I/ARB in patients with stable IHD on development of angioedema | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0
The impact of ACE-I/ARB in patients with stable IHD on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0.0% (0) | 0

ACE-I(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; CVA = cerebrovascular accident; IHD = ischemic heart disease; LV = left ventricular; MI = myocardial infarction; PICO = population, interventions, comparators of interest, and outcomes

Table D4 Ranking of research priorities using top five ranking score

Rank | Research area
1 | The impact of ACE-I/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.)
2 | The impact of ACE-I/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function)
3 | The benefit of ACE-I/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD
3 | Strategies to enhance greater evidence-based use of ACE-Is/ARBs
4 | Impact of demographic differences (such as age, race, sex) on ACE-I/ARB effectiveness or harms in patients with stable IHD
4 | The impact of ACE-I/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD
4 | The impact of ACE-I/ARB in patients with stable IHD on patient quality of life
5 | Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi- vessel coronary artery disease) on ACE-I/ARB effectiveness or harms in patients with stable IHD
6 | Impact of class effect (impact of differences between specific agents within each class) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
7 | Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE- I/ARB effectiveness or harms in patients with stable IHD
7 | The impact of ACE-I/ARB in patients with stable IHD on utilization and cost of therapy
8 | Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACE-I/ARB effectiveness or harms in patients with stable IHD
9 | The impact of ACE-I/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence
10 | Impact of the dose response (impact of medication dose or dosing interval) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
10 | The impact of ACE-I/ARB in patients with stable IHD on development of angioedema
10 | The impact of ACE-I/ARB in patients with stable IHD on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia)

ACE-I(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; CVA = cerebrovascular accident; IHD = ischemic heart disease; LV = left ventricular; MI = myocardial infarction; PICO = population, interventions, comparators of interest, and outcomes

## Results of Prioritization Exercise 2

Table D5 Research area ranking and summary statistics after Prioritization Exercise 2

| E: Evidence-based use | J: New diagnoses | A: Comorbidities | K: Quality of life | B: Demographic differences | F: Adherence | I: Alternative medication | L: Cardiovascular outcomes | M: Utilization and cost | N: Renal insufficiency | C: Concurrent medications | D: Genetic differences | H: Class effect | G: Dose response | O: Non-angioedema adverse effects | P: Angioedema
Stakeholder 1 | 16 | 2 | 4 | 7 | 12 | 9 | 6 | 5 | 13 | 3 | 10 | 11 | 1 | 8 | 14 | 15
Stakeholder 2 | 1 | 8 | 12 | 5 | 4 | 7 | 2 | 15 | 6 | 10 | 11 | 3 | 16 | 9 | 14 | 13
Stakeholder 3 | 4 | 5 | 9 | 3 | 7 | 2 | 6 | 1 | 10 | 14 | 8 | 11 | 12 | 13 | 16 | 15
Stakeholder 4 | 16 | 2 | 3 | 6 | 7 | 13 | 11 | 1 | 15 | 5 | 4 | 8 | 12 | 14 | 9 | 10
Stakeholder 5 | 5 | 3 | 1 | 13 | 4 | 6 | 8 | 2 | 12 | 11 | 7 | 15 | 9 | 10 | 14 | 16
Stakeholder 6 | 2 | 3 | 11 | 10 | 7 | 1 | 13 | 8 | 5 | 9 | 12 | 16 | 14 | 15 | 4 | 6
Stakeholder 7 | 1 | 15 | 5 | 4 | 6 | 2 | 8 | 13 | 3 | 14 | 9 | 11 | 7 | 10 | 12 | 16
Stakeholder 8 | 1 | 9 | 5 | 6 | 8 | 15 | 7 | 16 | 3 | 2 | 11 | 4 | 13 | 12 | 10 | 14
SUMMARY
Rank | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16
Average score | 5.8 | 5.9 | 6.3 | 6.8 | 6.9 | 6.9 | 7.6 | 7.6 | 8.4 | 8.5 | 9.0 | 9.9 | 10.5 | 11.4 | 11.6 | 13.1
Minimum score | 1 | 2 | 1 | 3 | 4 | 1 | 2 | 1 | 3 | 2 | 4 | 3 | 1 | 8 | 4 | 6
Maximum score | 16 | 15 | 12 | 13 | 12 | 15 | 13 | 16 | 15 | 14 | 12 | 16 | 16 | 15 | 16 | 16
SD | 6.50 | 4.55 | 3.96 | 3.28 | 2.53 | 5.22 | 3.34 | 6.32 | 4.72 | 4.69 | 2.62 | 4.67 | 4.75 | 2.50 | 3.85 | 3.48
Variance | 42.21 | 20.70 | 15.64 | 10.79 | 6.41 | 27.27 | 11.13 | 39.98 | 22.27 | 22.00 | 6.86 | 21.84 | 22.57 | 6.27 | 14.84 | 12.13
Median score | 3 | 4 | 5 | 6 | 7 | 6.5 | 7.5 | 6.5 | 8 | 9.5 | 9.5 | 11 | 12 | 11 | 13 | 14.5
1st quartile | 1 | 2.75 | 3.75 | 4.75 | 5.5 | 2 | 6 | 1.75 | 4.5 | 4.5 | 7.75 | 7 | 8.5 | 9.75 | 9.75 | 12.25
3rd quartile | 7.75 | 8.25 | 9.5 | 7.75 | 7.25 | 10 | 8.75 | 13.5 | 12.25 | 11.75 | 11 | 12 | 13.25 | 13.25 | 14 | 15.25

SD = standard deviation

Table D6 Ranking of 16 research areas after Prioritization Exercise 2

Ranking | Research area
1 | Strategies to enhance greater evidence-based use of ACE-Is/ARBs
2 | The impact of ACE-I/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function)
3 | Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACE-I/ARB effectiveness or harms in patients with stable IHD
4 | The impact of ACE-I/ARB in patients with stable IHD on patient quality of life
5 | Impact of demographic differences (such as age, race, sex) on ACE-I/ARB effectiveness or harms in patients with stable IHD
6 | The impact of ACE-I/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD
7 | The benefit of ACE-Is/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD
8 | The impact of ACE-I/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, non-fatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.)
9 | The impact of ACE-I/ARB in patients with stable IHD on utilization and cost of therapy
10 | The impact of ACE-I/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence
11 | Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACE-I/ARB effectiveness or harms in patients with stable IHD
12 | Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE-I/ARB effectiveness or harms in patients with stable IHD
13 | Impact of class effect (impact of differences between specific agents within each class) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
14 | Impact of the dose response (impact of medication dose or dosing interval) of ACE-Is and ARBs on their effectiveness or harms in patients with stable IHD
15 | The impact of ACE-I/ARB in patients with stable IHD on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia)
16 | The impact of ACE-I/ARB in patients with stable IHD on development of angioedema

ACE-I(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; CVA = cerebrovascular accident; IHD = ischemic heart disease; LV = left ventricular; MI = myocardial infarction; PICO = population, interventions, comparators of interest, and outcomes

## Prioritization Exercise 3 Results

Table D7 Research area ranking and summary statistics after Prioritization Exercise 3

| E: Evidence-based use | F: Adherence | A: Comorbidities | K: Quality of life | B: Demographic differences | J: New diagnoses | I: Alternative medication | M: Utilization and cost | L: Cardiovascular outcomes | C: Concurrent medications | N: Renal insufficiency | D: Genetic differences | G: Dose response | H: Class effect | O: Non-angioedema adverse effects | P: Angioedema
Stakeholder 1 | 12 | 6 | 2 | 3 | 5 | 1 | 7 | 13 | 4 | 11 | 8 | 14 | 10 | 9 | 15 | 16
Stakeholder 2 | 1 | 6 | 7 | 4 | 2 | 8 | 9 | 3 | 10 | 11 | 12 | 5 | 14 | 13 | 15 | 16
Stakeholder 3 | 1 | 3 | 6 | 2 | 8 | 4 | 7 | 9 | 5 | 12 | 10 | 11 | 14 | 13 | 16 | 15
Stakeholder 4 | 1 | 7 | 2 | 3 | 5 | 4 | 6 | 10 | 9 | 8 | 11 | 12 | 14 | 13 | 15 | 16
Stakeholder 5 | 1 | 4 | 3 | 6 | 5 | 2 | 8 | 10 | 7 | 9 | 11 | 12 | 13 | 14 | 15 | 16
Stakeholder 6 | 1 | 2 | 9 | 3 | 8 | 10 | 6 | 4 | 7 | 5 | 11 | 16 | 12 | 15 | 14 | 13
Stakeholder 7 | 1 | 2 | 4 | 7 | 5 | 6 | 9 | 3 | 10 | 8 | 11 | 13 | 12 | 14 | 15 | 16
Stakeholder 8 | 2 | 4 | 3 | 11 | 5 | 1 | 6 | 12 | 7 | 16 | 8 | 10 | 14 | 13 | 9 | 15
Stakeholder 9 | 1 | 5 | 4 | 2 | 3 | 14 | 10 | 9 | 16 | 8 | 15 | 11 | 6 | 12 | 13 | 7
SUMMARY
Rank | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16
Original Rank | 1 | 6 | 3 | 4 | 5 | 2 | 7 | 9 | 8 | 11 | 10 | 12 | 14 | 13 | 15 | 16
Average score | 2.3 | 4.3 | 4.4 | 4.6 | 5.1 | 5.6 | 7.6 | 8.1 | 8.3 | 9.8 | 10.8 | 11.6 | 12.1 | 12.9 | 14.1 | 14.4
Minimum score | 1 | 2 | 2 | 2 | 2 | 1 | 6 | 3 | 4 | 5 | 8 | 5 | 6 | 9 | 9 | 7
Maximum score | 12 | 7 | 9 | 11 | 8 | 14 | 10 | 13 | 16 | 16 | 15 | 16 | 14 | 15 | 16 | 16
SD | 3.64 | 1.80 | 2.40 | 2.96 | 1.96 | 4.42 | 1.51 | 3.82 | 3.54 | 3.15 | 2.11 | 3.05 | 2.67 | 1.69 | 2.09 | 2.96
Variance | 13.25 | 3.25 | 5.78 | 8.78 | 3.86 | 19.53 | 2.28 | 14.61 | 12.50 | 9.94 | 4.44 | 9.28 | 7.11 | 2.86 | 4.36 | 8.78
Median score | 1 | 4 | 4 | 3 | 5 | 4 | 7 | 9 | 7 | 9 | 11 | 12 | 13 | 13 | 15 | 16
1st quartile | 1 | 3 | 3 | 3 | 5 | 2 | 6 | 4 | 7 | 8 | 10 | 11 | 12 | 13 | 14 | 15
3rd quartile | 1 | 6 | 6 | 6 | 5 | 8 | 9 | 10 | 10 | 11 | 11 | 13 | 14 | 14 | 15 | 16

SD = standard deviation