# Appendix C Details of Research-Sponsoring Organizations

## List of Organizations Sponsoring Research

Note: Organizations that declined participation or did not provide a response are noted with an asterisk.

### National Institutes of Health: Centers, Programs, and Individual Institutes

1. Division of Program Coordination, Planning and Strategic Initiatives, Office of Director, NIH*
2. Office of AIDS Research
3. Office of Behavioral and Social Sciences Research (OBSSR)
4. Office of Strategic Coordination (OSC), Office of Director, NIH*
5. Office of Research in Women’s Health
6. National Cancer Institute (NCI)
7. National Eye Institute (NEI)
8. National Heart, Lung and Blood Institute (NHLBI)
9. National Human Genome Research Institute (NHGRI)
10. National Institute of Aging(NIA)
11. National Institute of Alcohol Abuse and Alcoholism (NIAAA)
12. National Institute of Allergy and Infectious Diseases (NIAID)
13. National Institute of Arthritis, Musculoskeletal and Skin Diseases (NIAMS)*
14. National Institute of Biomedical Imaging and Bioengineering (NIBIB)*
15. National Institute of Child Health and Human Development (NICHD)
16. National Institute on Deafness and other Communication Disorders (NIDCD)*
17. National Institute of Dental and Craniofacial Research (NIDCR)
18. National Institute of Digestive and Kidney Diseases (NIDDK)*
19. National Institute of Drug Abuse (NIDA)
20. National Institute of Environmental Health Science (NIEHS)
21. National Institute of General Medical Sciences (NIGMS)*
22. National Institute of Mental Health (NIMH)
23. National Institute of Neurological Disorders and Stroke (NINDS)*
24. National Institute of Nursing Research (NINR)*
25. NIH Consensus Statements

### Agency for Healthcare Research and Quality (AHRQ)

26 United States Preventive Services Task Force (USPSTF)
27 Developing Evidence to Inform Decisions about Effectiveness Network (DeCIDE) Centers
28 Centers for Education & Research on Therapeutics (CERTs)
29 Topic Selection for Systematic Reviews

### Other U.S. Government Sponsors of Research

30 Centers for Disease Control and Prevention (CDC)*
31 Centers for Medicare and Medicaid Services (CMS)*
32 Veterans Administration (VA)*
33 U.S. Food and Drug Administration (FDA)*
34 U.S Agency for International Development (USAID)

### International Agencies and Groups

35 National Institute for Clinical Excellence (NICE)
36 Cochrane reviews and protocols
37 Canadian Agency for Drugs and Technologies in Health
38 Canadian Institutes for Health Services Research and Policy
39 German Research Foundation
40 German Federal Ministry of Education and Research
41 Australian Research Council
42 World Health Organization

### Nongovernmental Sponsors of Research

43 American Cancer Society
44 Bill and Melinda Gates Foundation
45 Robert Wood Johnson Foundation*
46 American Heart Association
47 March of Dimes*
48 Children’s Health and Nutrition Research Initiative of the Global Forum for Health Research

## Summary Table

1. | Agency for Health Care and Quality (AHRQ)
| a. Focus | - Identifying, Selecting, and Refining Topics for Comparative Effectiveness Systematic Reviews
| b. Criteria | - Appropriateness—applies to Medicare and/or Medicaid populations, priority condition designated by the Department of Health and Human Services (DHHS); - Importance-disease burden, cost-of illness, strong stakeholder support, uncertainty or controversy surrounding issue; - Desirability of new research/duplication; - Feasibility; - Potential value-potential for significant health and economic impact, potential for change and potential risk from inaction; addresses inequities, vulnerable populations, and has clear implications for resolving dilemmas in health and health care decisions
| c. Methods | - Consensus-based; expert-panel (topic prioritization group) with input from multiple stakeholders.
| d. Source | - Whitlock et al., 2010^1^
2 | AHRQ-Centers for Education and Research on Therapeutics (CERTs)
| a. Focus | - Prioritizing new research
| b. Criteria | - None
| c. Methods | - Investigator-initiated research prioritized by peer-review process; no other formal prioritization process.
| d. Source | - Response to Duke EPC review of research priority setting methods
3 | AHRQ-DEcIDE (Developing Evidence to Inform Decisions about Effectiveness) Network
| a. Focus | - Prioritizing new research
| b. Criteria | - Appropriateness—applies to Medicare and/or Medicaid populations, priority condition designated by the Department of Health and Human Services (DHHS); - Importance-disease burden, cost of illness, strong stakeholder support, uncertainty or controversy surrounding issue; - Desirability of new research/duplication; - Feasibility; - Potential value-potential for significant health and economic impact, potential for change and potential risk from inaction; addresses inequities, vulnerable populations, and has clear implications for resolving dilemmas in health and health care decisions
| c. Methods | - Consensus-based
| d. Source | - Response to Duke EPC review of research priority-setting methods
4 | U.S. Preventive Services Task Force
| a. Focus | - Identifying research priorities for clinical preventive services
| b. Criteria | - Public health importance (burden of suffering, and expected effectiveness of preventive services to reduce that burden);; - Potential for a Task Force recommendation to affect clinical practice (based on existing controversy or the belief that a gap exists between evidence and practice);; - New evidence (e.g., new studies or new analysis of previous data) that has the potential to change prior recommendations;; - Need for a balanced portfolio of topics.
| c. Methods | - Consensus-based
| d. Source | - http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual2.htm
5 | National Institute of Clinical Excellence (NICE), UK
| a. Focus | - Topic selection for the Institute’s clinical practice, health technologies and public health programs
| b. Criteria | - Identified as priority by the health service or the government; - Impact on the financial or other resources of the NHS or society in general; - Interventions that the NHS could stop using without impairing cost-effective patient care, thus freeing up resources for use elsewhere in the NHS; - Significant morbidity or mortality; - Interventions or practices that could:; - significantly improve patients’ or carers’ quality of life; - reduce avoidable morbidity; - reduce avoidable premature mortality; - reduce inequalities in health?; - Variations in clinical practice; - Variation in access to interventions or treatment; - Significant public concern
| c. Methods | - Consensus based; expert panel deliberations with input from stake holders
| d. Source | - http://www.nice.org.uk/niceMedia/pdf/boardmeeting/brdnov06item4.pdf
5.a | National Institute of Clinical Excellence (NICE), UK
| a. Focus | - Translating uncertainties identified in systematic reviews into research recommendations
| b. Criteria | Suggested criteria for evaluation; - Importance to patients or the population; - Relevance to NICE Guidance; - Relevance to NHS; - National priorities; - Current evidence base; - Equality; - Feasibility
| c. Methods | - Consensus-based;; - Decisionmaking framework employed recommends use of value-of-information methods (as and when necessary) to reduce evidence gaps and help prioritize future research
| d. Source | http://www.nice.org.uk/media/46F/72/ResearchRecommendationManual.pdf
6 | Cochrane Reviews
| a. Focus | - Topic selection for systematic assessment of health care interventions
| b. Criteria | - Burden of disease, magnitude of problem, urgency; - Importance to developing countries; - Avoidance of duplication; - Opportunity for action
| c. Methods | - Consensus-based
| d. Source | - Waters et al, 2003^2^
7 | World Health Organization
| a. Focus | - Improving the use of research evidence in guideline development
| b. Criteria | - High burden of illness; - No existing guidelines or recommendations of good quality; - Feasibility of developing recommendations; - Implementation is feasible; - Interventions that will likely require systems changes; - Interventions where there might be conflict in choices between individual and societal perspectives
| c. Methods | - Consensus-based;
| d. Source | - Oxman et al., 2006^3^
| National Institutes of Health and Individual Institutes and Centers within the NIH
8 | National Heart and Lung Institute (NHLBI), NIH
| a. Focus | Identifying institute-level research priorities
| b. Criteria | - Alignment with the NHLBI Strategic Plan; - Magnitude of the public health need (disease severity, number affected, current therapy); - Existence of scientific opportunity (new concepts or tools, likelihood of significant advance); - Rate of research progress; - Opportunity to attract disciplines new to NHLBI research areas; - Need to foster multidisciplinary research; - Expression of congressional interest
| c. Methods | - Consensus-based with input from researchers, advisory council and a variety of stake holders; - Extramural, investigator initiated research (70% of research funding) is prioritized using peer-review system; - Institute-initiated research (30%) is prioritized by NHLBI staff through working groups and advisory council of outside experts.; - Proposed research in applications with direct costs of $500,000 or more in any one year are prioritized based on whether research is: 1. relevant to NHLBI mission, 2. complements outgoing or new NHLBI programs, 3. adds to existing knowledge, 4. has reasonable costs and 5. has appropriate plans for data sharing
| d. Source | - Response to Duke EPC review of research priority-setting methods
9 | National Institute of Aging (NIA), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Responding to needs identified by NIH/presidential/congressional leaders; - Burden of illness/disease prevalence/trends among aging population groups; - Scientific opportunity; - Special areas or needs identified using bibliometric and portfolio analysis
| c. Methods | - Consensus-based with ongoing input from research community and advisory groups and advocacy organizations
| d. Source | - Response to Duke EPC review of research priority-setting methods
10 | National Institute of Allergy and Infectious Diseases (NIAID), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Need or gap; - Scientific opportunity; - Portfolio diversification; - Public health need
| c. Methods | - Consensus-based through the mechanism of scientific workshops, program reviews, research advisory committees, blue ribbon panels and input from stakeholders
| d. Source | - Response to Duke EPC review of research priority-setting methods (See Appendix)
11 | National Institute of Dental and Craniofacial Research (NIDCR), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Prevalence and impact of related diseases and criterion; - Current state of science (and available opportunities); - Responding to needs identified by NIH/Presidential/Congressional leaders
| c. Methods | - Consensus-based with input from research community, professional societies, patient organizations, Board of scientific councilors and ad-hoc advisory groups
| d. Source | - Response to Duke EPC review of research priority-setting methods
12 | National Institute on Drug Abuse (NIDA), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Emerging and significant public health needs; - Key scientific opportunities; - Filling gaps in current knowledge base
| c. Methods | - Consensus-based with input from research community, professional societies, patient organizations, Board of scientific councilors and ad-hoc advisory groups, U.S. Administration representatives and Members of Congress; - Input on the priority setting process from:; - NIDA Council –The National Advisory Council on Drug Abuse with 18 members including 12 scientific experts, 6 knowledgeable members of the general public, and ex-officio members who provide liason with other government entities. Council advises on the institute’s program portfolio and helps determine the overall merit and priority of grant applications; - Subcommittees of the Advisory Council to systematically review NIDA’s portfolio and issue recommendations to the director; - Conferences and symposia: Variety of meetings to solicit potential scientific research in particular areas identified as a priority; - Monitoring of emerging health needs: Monitoring of national and regional drug abuse trends to identify and prioritize specific areas of research
| d. Source | - Response to Duke EPC review of research priority-setting Methods
13 | National Eye Institute (NEI), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Not explicitly specified; broad criteria such as scientific opportunity as interpreted by panel of experts in the strategic planning process
| c. Methods | - Consensus-based
| d. Source | - Response to Duke EPC review of research priority-setting methods
14 | NIH Consensus Development Program
| a. Focus | - Prioritizing topics for evidence-based consensus statements addressing controversial issues important to health care providers, policymakers, patients, researchers, and the general public
| b. Criteria | - None
| c. Methods | - Informal consensus-based process
| d. Source | - Response to Duke EPC review of research priority-setting methods
15 | Office of Research on Women’s Health, NIH
| a. Focus | - Developing strategic research priorities for women’s health research for the coming decade
| b. Criteria | - Not explicitly specified
| c. Methods | - Regional scientific workshops and public hearings with participation from leading scientists, women’s health advocates, public policy experts, healthcare providers, and the general public; participants provide both written as well as public testimony. Ideas from regional workshops integrated with additional input from NIH community over the course of a 18-month national planning effort to develop strategic research priorities for women’s health research.
| d. Source | - Response to Duke EPC review of research priority-setting methods
16 | National Human Genome Research Institute (NHGRI), NIH
| a. Focus | - Setting institution-wide priorities for investigator-initiated research as well as institute-initiated research.
| b. Criteria | - Not explicitly specified; broad priorities are scientific merit and fidelity to the institute’s mission
| c. Methods | Priorities set using consensus-based methods in consultation with the research community and stakeholders through the following methods:; - Workshops and conferences sponsored by NHGRI; - Concept clearance from the National Advisory Council for Human Genome Research; - Request for White Papers; - Regular long-range planning activities (see www.genome.gov/Planning)
| d. Source | - Response to Duke EPC review of research priority-setting methods
17 | Office of Behavioral and Social Research (OBSSR), NIH
| a. Focus | - Behavioral and social research across NIH
| b. Criteria | - Not explicitly defined;
| c. Methods | - Consensus-based methods
| d. Source | - Response to Duke EPC review of research priority-setting methods
18 | National Institute of Child Health and Human Development (NICHD), NIH
| a. Focus | - Identifying institute-level research priorities
| b. Criteria | - Responsiveness to existing and emerging public health needs; - Disease burden (incidence, severity, and costs of specific disorders); - Considerations such as unmet needs associated with rare disorders
| c. Methods | - Consensus-based with input from many sources, including:; - Formally instituted advisory and review panels including National Child Health and Human Development Advisory Council, the National Advisory Board for Medical Rehabilitation Research and the NICHD board of scientific councilors; - The extramural scientific community, including individual researchers and professional societies;; - Patient and provider organizations and voluntary health organizations, which may provide input directly or indirectly, through Congress and the media;; - Congress and the Administration;; - NIH leadership and colleagues at other NIH ICs;; - Formally constituted advisory and review panels described below;; - NICHD staff scientists;; - Research programs of other Federal agencies such as the Department of Defense and the Department of Education;; - International public health and research organizations; and; - Individual members of the public
| d. Source | - Response to Duke EPC review of research priority-setting methods
19 | National Cancer Institute
| a. Focus | - Setting institutional priorities
| b. Criteria | - Not explicitly defined
| c. Methods | - Consensus-based process with input from multiple stakeholders; consensus developed through multiple forums including state-of-science workshops, scientific advisory boards program reviews, meetings
| d. Source | - Response to Duke EPC review of research priority-setting; - http://www.cancer.gov/aboutnci/servingpeople/BudgetProcess
20 | USAID
| a. Focus | - Identifying priority problems for research
| b. Criteria | - Relevance (to USAID’s strategic priorities); - USAID’s unique role; - Importance of the problem; - Consistency; - Feasibility; - U.S. Institution’s unique role
| c. Methods | - Consensus-based methods;; - The research policy framework of USAID recommends use of appropriate analytical tools (e.g. cost-benefit analysis, cost-effectiveness analysis) to facilitate use of these criteria and to determine the relative value of USAID research efforts
| d. Source | - Response to Duke EPC review of research priority-setting methods; (http://www.usaid.gov/policy/ads/200/polframe.pdf)
21 | Office of AIDS Research
| a. Focus | - Trans-NIH AIDS research agenda and priorities
| b. Criteria | - Public health need; - Scientific opportunity
| c. Methods | - Consensus-based methods
| d. Source | - Response to Duke EPC Review of Research Priority Setting Methods; (http://www.usaid.gov/policy/ads/200/polframe.pdf)
| c. Methods | - Consensus-based methods; Input from internal staff, research community, other NIH institutes and centers,; - Portfolio analysis; - Concept mapping; - Request for information in the NIH guide asking for members of the public, advocacy groups, scientific organizations, researchers etc to identify priorities for future research investments
| d. Source | - http://obssr.od.nih.gov/pdf/bBSSR%20StrategicPlanOBSSR%20FINAL.pdf; - http://obssr.od.nih.gov/pdf/OBSSR_Prospectus.pdf
22 | National Institute of Alcohol Abuse and Alcoholism
| a. Focus | - Institute-level priorities
| b. Criteria | - Multiple; not specified explicitly
| c. Methods | - Consensus-based methods; Input from public, scientists, NIAAA advisory council and working groups
| d. Source | - Response to Duke EPC review of research priority setting methods
23 | National Institutes of Environmental Health Sciences
| a. Focus | - Setting institute-wide priorities
| b. Criteria | - Scientific opportunity; - Public health importance; - Impact on research portfolio (focus on research areas where NIEHS has genuine strengths)
| c. Methods | - Consensus-based methods using with input from variety of sources such as National advisory environmental health services council, annual leadership retreat, board of scientific counselors, research workshops, semi-annual center director’s meetings, and the general public
| d. Source | - Response to Duke EPC review of research priority setting methods
24 | National Institute of Mental Health (NIMH)
| a. Focus | - Setting institutewide priorities
| b. Criteria | - Multiple; not specified explicitly
| c. Methods | - Consensus-based methods
| d. Source | - Response to Duke EPC review of research priority setting methods
25 | Institute for Health Services and Policy Research (IHSPR), Canada
| a. Focus | Priorities for health services research across Canada-
| b. Criteria | Multiple; not specified explicitly
| c. Methods | Consensus-based; Research priorities identified with input from a broad range of stakeholders and potential partners (input is typically obtained through a range of mechanisms including key informant interviews, town hall meetings, in-person meetings with partners, etc.), refined by various subcommittees of the board (comprised of IHSPR’s board members and a few key experts from the researcher and decision maker communities), and vetted by Institute Advisory Board for final approval. Specific example: IHSPR in partnership with Canadian Health Services Research Foundation (CHSRF) implements a national consultation process-Listening for Direction (LFD)- a pan-Canadian priority setting exercise undertaken every three years to identify pressing short, medium and long-term priority issues of the health system decision makers and managers from across the country with regards to health services research and policy.
| d. Source | Response to Duke EPC review of research priority-setting methods
26 | American Cancer Society
| a. Focus | Prioritization of research portfolio
| b. Criteria | None
| c. Methods | Primarily investigator initiated, peer-reviewed research; A small portion of ACS research goes to focused research and the specific areas are chosen by panels of outside scientists and ACS volunteer leadership
| d. Source | Response to Duke EPC review of research priority-setting methods
27 | American Heart Association
| a. Focus | Prioritization of research portfolio
| b. Criteria | None
| c. Methods | None; Primarily investigator initiated research; No formal prioritization process
| d. Source | Response to Duke EPC review of research priority-setting methods
28 | German Research Foundation
| a. Focus | Prioritization of research portfolio
| b. Criteria | Primarily science driven;
| c. Methods | Does not set research priorities
| d. Source | Response to Duke EPC review of research priority-setting methods
29 | Australian Research Council
| a. Focus | Prioritization of research portfolio
| b. Criteria | None
| c. Methods | Does not set research priorities; acts on guidance received from Australian government on areas of research of national priority
| d. Source | Response to Duke EPC review of research priority-setting methods
30 | Canadian Agency for Drugs and Technologies in Health
| a. Focus | Priority setting for health technology assessment
| b. Criteria | Disease burden Clinical impact Alternatives Budget Impact Economic Impact Available Evidence
| c. Methods | Deliberative process incorporating ranking using specific criteria
| d. Source | Husereau et al., 2010^4^
31 | Child Health and Nutrition Research Initiative of the Global Forum for Health Research
| a. Focus | Priority setting for research into child health and nutrition issues in developing world
| b. Criteria | Answerability Effectiveness Deliverability Maximum potential for disease burden reduction Effect on equity
| c. Methods | Deliberative process incorporating ranking using specific criteria involving both stakeholders and investors in research
| d. Source | http://www.chnri.org/

References to Summary Table:

1 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol 2010;63(5):491–501.

2 Waters E, Doyle J, Jackson N. Evidence-based public health: improving the relevance of Cochrane Collaboration systematic reviews to global public health priorities. J Public Health Med 2003;25(3):263–266.

3 Oxman AD, Schunemann HJ, Fretheim A. Improving the use of research evidence in guideline development: 2. Priority setting. Health Res Policy Syst 2006;4:14.

4 Husereau D, Boucher M, Noorani H. Priority setting for health technology assessment at CADTH. Int J Technol Assess Health Care 2010;26(3):341–347.