# Appendix B Data Abstraction Form

Study | Study characteristics and participants | Focus of prioritization effort | Identification of research gaps | Prioritization considerations and methods | Use of prioritization results/study output
Study ID and location: [enter information] 1st author___________ Year____________ Article #_________ | Location: [enter country]________ Study type: [check one/delete all but one] ___Methodologi cal with case study ___Practical application of priority setting framework/process (e.g., report of consensus conference) Sponsoring organization: [check multiple items, if appropriate] ___NIH ___AHRQ ___Other US govt Describe:________ ___Non-US govt Describe:________ ___WHO ___NGO ___Professional society ___Advocacy group (e.g., AHA, ACS) __Industry ___Academic Specify source of funding: Govt___ Industry___ Nonprofit___ Not reported__ Participants: [give N for each category as appropriate] Researchers____ Sponsoring agency____ Other agencies____ Payers____ Industry____ Advocacy org____ Patients____ Providers/clinicians____ | Focus of prioritization effort: [check one/delete all but one] ___Provider/specialty based (e.g., research questions in acute care nursing) ___Broad disease area (e.g., breast cancer vs. prostate cancer vs. colon cancer) ___Specific disease (e.g., screening vs. improved treatment for breast cancer) Describe:__________ ___Specific interventions (e.g., mammography vs. MRI for screening high-risk women) ___Specific methods (e.g., RCTs vs. registries for CER) | Identification of research gaps: [check multiple items, if appropriate] ___Systematic review specifically for this article ___Cited systematic reviews ___Non-systematic review specifically for this article ___Cited non-systematic review ___Formal survey prior to conference/work group meeting ___Formal survey at conference/work group meeting ___Non-specific consensus of participants ___Other Describe:________ ___None ___Not specified | Prioritization considerations: [check multiple items, if appropriate] ___Burden of disease ___Cost of illness ___Feasibility ___Impact on practice ___Clinical variations (gap between current practice and best practice) ___Inclusiveness (relevance of research area to broad range of individuals with regard to age, sex, socioeconomic status and race or ethnicity) ___Value of research ___Other Describe:___________ ___Not specified Prioritization methods: [check multiple items, if appropriate] 1. Consensus based methods: ___Qualitative survey ___Quantitative survey ___Delphi ___Other (e.g., deliberations among work group members/panel, voting) 2. Modeling-based approaches: ___VOI analysis ___Cost effectiveness ___Probabilistic decision analytic model ___Other Describe:______ ___Not specified | Use of prioritization results: [check multiple items, if appropriate] ___Allocation of research funds (e.g., RFA/RFP) ___Setting a research agenda __Adoption/further research for a particular technology or intervention ___Advocacy ___Not specified Study output: [check multiple items, if appropriate] ___Ranked list of priorities (yes/no) ___Identification of broad research questions without ranking ___Cost-effectiveness of therapy/intervention ___Cost-effectiveness of research ___Cost-effectiveness of research and EVPI