# Appendix A Literature Search and Screening Results

## Search Strategies

We performed two PubMed^®^ searches to identify published studies relevant to this review. These searches were structured as described below.

[underlined: Search #1]: Designed to identify articles addressing methods of priority setting, using the following search strategy (no date restrictions, search date October 22, 2010):

("Research"[Mesh] OR "Health Services Research"[Mesh]) AND (exercise[title/abstract] OR tool[title/abstract] OR tools[title/abstract] OR model[title/abstract] OR models[title/abstract] OR method[title/abstract] OR methods[title/abstract] OR "models, theoretical"[MeSH Terms] OR "costs and cost analysis"[MeSH Terms] OR "resource allocation"[MeSH Terms] OR "investments/economics"[Mesh Terms]) AND ("health priorities"[MeSH Terms] OR "priority setting"[title/abstract] OR "research priorities"[title/abstract] OR "research priority"[title/abstract])

[underlined: Search #2]: Designed to identify articles specifically addressing VOI, using the following search strategy (no date restrictions, search date December 1, 2010):

"value of information"[title/abstract] AND (("Decision Making"[Mesh] OR "Decision Theory"[Mesh]) OR ("Research"[Mesh] OR "Health Services Research"[Mesh]) OR research[title/abstract])

## Literature Screening Results

Figure A1 summarizes the results of our literature search and screening.

Figure A1 Literature flow diagram

Figure A1. is a literature flow diagram showing 1,173 citations identified by MEDLINE literature searches including 1,038 research priority searches and 135 VOI searches; 1,237 citations were screened at the title/abstract level, 519 citations were screened at the full-text level and 214 citations were abstracted; numbers of duplicate and excluded citations are noted in the diagram.