# Acronyms and Abbreviations

ACEI(s): angiotensin-converting enzyme inhibitor(s)
AHRQ: Agency for Healthcare Research and Quality
ARB(s): angiotensin II receptor antagonist(s)
ARRA: American Recovery and Reinvestment Act of 2009
CADTH: Canadian Agency for Drugs and Technologies in Health
CER: comparative effectiveness review
CHF: congestive heart failure
CMTP: Center for Medical Technology Policy
DEcIDE: Developing Evidence to Inform Decisions about Effectiveness
EPC: Evidence-based Practice Center
ESRD: end-stage renal disease
EVPI: expected value of perfect information
EVPPI: expected value of partial perfect information
FUS: focused ultrasound
HTA: Health Technology Assessment
ICER: incremental cost-effectiveness ratio
IHD: ischemic heart disease
LV: left ventricular
LY: life-year
MI: myocardial infarction
MRI: magnetic resonance imaging
NICE: National Institute for Clinical Excellence
NIH: National Institutes of Health
QALY: quality-adjusted life year
RTI: Research Triangle Institute
TEP: Technical Expert Panel
TWG: Technical Working Group
UAE: uterine artery embolization
UK: United Kingdom
UNC: University of North Carolina at Chapel Hill
USAID: U.S. Agency for International Development
VOI: value of information/value-of-information
WHO: World Health Organization
WTP: willingness to pay