# Results

## Phase 1: Literature Summary

After the exclusion of editorials, commentaries, and studies that did not provide data for stakeholder engagement, 67 articles provided information about methods for engaging stakeholders, of which 56 focused specifically on engaging stakeholders to prioritize research (Figure 2).

Figure 2 Results from literature search

Figure 2. Literature search results. 152 abstracts were selected and of those, 20 were excluded. 132 full-text articles and an Institute of Medicine report were reviewed and of these, 66 were excluded. Reasons for abstract and full-text article exclusion included no data, not health research and conceptual/theoretical modeling. 67 articles engaged stakeholder and of those, 53 engaged stakeholders to prioritize future research.

### Definition of Stakeholder and Stakeholder Groups

We found that the term “stakeholder” and the categorization of stakeholder groups were inconsistently applied by researchers. For the purposes of this report, stakeholders are individuals or organizations who have a personal or professional interest in the topic. We developed operational definitions of the major categories of stakeholders based on definitions, terms, and stakeholder categories reported by researchers (Table 1).

Table 1 Definitions of stakeholder groups

Stakeholder | Definition
Consumer (general public, patient, and caregiver) | An individual or advocacy group representing individuals who use health care services (e.g., patients and their families) and/or who is a member of the community (e.g., patient, parent, neighbor); - General public; - General public advocacy group; - Individual patient with condition/disease; - Individual patient without condition/disease; - Patient advocacy group – condition/disease specific; - Patient advocacy group – not condition/disease specific; - A person acting as a proxy or providing care to a patient with condition/disease
Clinician (Health Professional) | Health care provider (academic, rural/frontier, community); - Condition/disease specific; - Not condition/disease specific; - Practicing/nonpracticing; Medical organizations; - Condition/disease specific; - Not condition/disease specific
Policymaker | An individual or organization who is involved in health care policy (e.g., local, state, provincial and Federal legislators and staff); - Medical organizations; - Governmental organizations (e.g., VA, AHRQ, government officials)
Researcher | An individual who conducts and/or facilitates research activities:; - Basic science; - Translational science; - Clinical science; - Research methodology; - Health service; - Systematic review
Research Funder | A public or private organization that funds research (e.g., National Institute of Health, Department of Defense, Robert Wood Johnson Foundation, Susan G. Komen Foundation, American Cancer Society)
Insurer/Payer | An organization or agency that pays for health-related goods and services (e.g., Blue Cross Blue Shield, Medicaid, Medicare) or a business group that pays for health insurance (e.g., employers and government)
Manufacturer | A business group that produces health-related items (e.g., pharmaceuticals and medical devices)

Abbreviations: AHRQ, Agency for Healthcare Research and Quality; VA, Veterans Affairs.

Note: It is possible for stakeholders to represent multiple perspectives and stakeholder groups. For example, Medicaid directors could be both Policymakers and Insurers/Payers.

### A Priori Identification of Relevant Stakeholder Groups

An important step to ensure that representative stakeholders are engaged is to list the relevant stakeholder groups prior to initiating recruitment. This step makes it possible to monitor and maintain representativeness of stakeholders during recruitment and analysis.

Identifying individuals or organizational stakeholder groups can be challenging. The methods that studies used to identify these groups are listed in Table 2. Snowball sampling was one of the most commonly reported methods used to identify stakeholders.6–8,9,7,10,11,21 It is thought to be a particularly useful method to identify members of special populations that are more difficult to locate (i.e., people with rare conditions). Because individuals may be more likely to recommend people who are similar to themselves, it is possible that bias could be introduced with this method or generalizability issues may arise. In contrast, random sampling, which is less likely to introduce bias, was the least common identification method used. Random sampling was reported for three studies that recruited the public, patients, health professionals, and researchers.8,12,13 But it may not always be feasible, for example, when searching for patients with rare health conditions.

Table 2 Literature results: Methods for identifying and selecting stakeholders

Stakeholders | Recommendations by Study Team^a,b^ | Snowball Sampling | Searching Published Literature | Searching Databases/Directories | Internet Searches of Individuals and Organizations | Random Sampling
Consumers | 7, 14–16 | 6–8 | | 13, 17, 18 | | 12, 13
Clinicians | 14, 19 | 9 | 15 | 9, 20 | 19 | 8
Policymakers | 14, 19, 21 | 7, 10, 11 | 11 | 20 | 19
Manufacturers | 19 | 10 | | | 19
Researchers | 14, 19 | 6, 7, 22 | 8, 10, 11, 15, 19 | 10, 20 | 19 | 8
Research Funders | | 7

a Numbers indicate citations (see References section).

b Blank cells indicate no studies found.

Note: Sampling methods not specified or incomplete description of methods.23–27

### Contacting Stakeholders

Once investigators identified the stakeholders that they wanted to reach, the next step was to choose a method for contacting stakeholders. Table 3 details the methods reported in the literature. Regardless of stakeholder group, investigators most commonly reported contacting stakeholders using postal and electronic mailings. Because many studies did not report recruitment details, we were unable to evaluate the effectiveness of these methods for each stakeholder group.

Table 3 Literature results: Methods for contacting stakeholders

Stakeholders | Postal Letters^a,b^ | E-mail | Phone Calls | Presentations/Informational Sessions | Advertisements in Journals, Newspapers, and Web | Posters
Consumers | 12, 17, 28–31 | 31, 32 | 17, 29, 32 | 31, 33, 34 | 17 | 35
Clinicians | 28, 30, 31 | 9, 16, 20, 31 | | 31, 36 | 37 | 38
Policymakers | 10, 28, 30, 31 | 10, 16, 20, 31 | | 31
Manufacturers | 10, 31 | 10, 31 | | 31
Researchers | 10, 28, 30, 31 | 10, 16, 20, 31 | | 31
Research Funders | 24 | 24

a Numbers indicate citations (see References section).

b Blank cells indicate no studies found.

### Engaging Stakeholders To Prioritize Research

The process of engaging stakeholders was intended to make research relevant to the real-world decisions faced by the public and clinicians. Table 4 lists the methods that researchers used to engage stakeholders in discussions about future research. Among the methods used, two may be less familiar than others—citizens’ juries and town meetings. Citizens’ juries bring together diverse members of the public as jurors who are given information relevant to the issue under debate by expert witnesses, followed by a facilitated discussion. The end result may be a report by the jurors or questionnaire responses from the jurors. Town meetings bring together community members in a public meeting to discuss issues of interest. Town meetings are often loosely organized, with a relaxed atmosphere. More detailed information about engagement methods appears in Appendix F (descriptions of the engagement methods found in the literature) and G (descriptions of each method’s strengths and limitations).

Table 4 Literature results: Methods used to engage stakeholders and prioritize research

| Engagement | | | | | Prioritization | | | Engagement and Prioritization
| 1:1 Meetings (in-person or telephone)^a,b^ | Focus Groups | Citizens’ Juries | Town-Meetings | Symposia/Workshops/Conferences/Forums | Consensus | Voting | Nominal Group Technique | One-Time Priority Questionnaire | Delphi Technique
Consumers | 11, 13, 14, 39 | 7, 13, 14, 16, 25, 26, 28, 29, 39–45 | 12, 17, 46, 47 | 48, 49 | 11, 30, 35, 43, 50 6, 32 | 13, 26, 31, 42, 44, 45, 48, 50, 51 | 31, 49 | 30, 52 | 8, 18, 34, 40, 43, 51, 53–55 | 15, 33, 38, 56, 57
Clinicians | 14, 16, 39 | 14, 19, 27, 39, 44, 48, 58 | | 48 | | 27, 31, 44, 48, 50, 51, 58 | 31 | 27, 28, 30, 52 | 8–10, 20, 51, 53–55 | 15, 33, 36–38, 56–59
Policymakers | 10, 11, 14, 16 | 7, 14, 19, 27, 44, 58 | | 48 | 11, 20, 21, 23, 30, 50, 60 | 23, 27, 31, 44, 48, 50, 58 | | 27, 30, 52 | 8, 10, 20, 21, 55 | 11, 28, 33, 56, 58
Manufacturers | | 19, 44 | | | | 31, 44, 50 | | 30, 52
Researchers | 14, 16, 28, 39 | 7, 14, 19, 22, 27, 39, 44, 45, 48, 58, 61 | | 48 | 6, 20, 23, 30, 50, 60 | 44, 48, 50 7, 27, 31, 45, 58, 60 | | 27, 28, 30, 52 | 8, 10, 20, 54, 55 | 11, 15, 28, 58
Research Funders | 24, 39 | 7, 44 | | | 14, 50, 60 | 44, 50 | | 30 | 8, 55

a Numbers indicate citations (see References section).

b Blank cells indicate no studies found.

Note: Methods of stakeholder engagement are described in Appendix F.

The methods for engaging stakeholders were largely determined by the intended purpose of stakeholder engagement (i.e., topic generation, study design, study implementation, policy development, and prioritization of research). Investigators most commonly reported engaging stakeholders to discuss research using in-person methods such as focus groups, forums, and conferences, either alone or in combination with other methods.7,14,16,23,25,29,38–43 In-person methods are advantageous because they allow for exchange of information to clarify participants’ questions and they elicit a deeper understanding of viewpoints through rich narratives. Investigators often used a structured system such as voting, Delphi, questionnaire, or other explicit rating process in concert with in-person methods to arrive at final priorities. However, two studies35,43 tallied the frequency that an item was mentioned during focus group discussions and used this process to provide a ranked list, and one study40 created a questionnaire from identified themes to determine final priorities.

The next most commonly reported prioritization methods were the Delphi or modified Delphi technique, used in seven studies,15,33,36,37,56,58,59 and rankings from responses to questionnaires. The Delphi technique administered a series of two to five questionnaires sequentially to a panel of stakeholders to rate or rank importance of items. After each round of questionnaires, answers were tabulated and fed back to participants to allow them to reorder or to arrive at consensus. Advantages of the Delphi method include: (1) Delphi questionnaires can be administered to large groups of people (studies reported ranged from 50 to 621 participants) across a wide geographical area; (2) the process is designed to arrive at consensus, thus a final rank list of priorities can be produced; (3) stakeholders may be more comfortable expressing their opinions in a less public venue; and (4) the method helps to ensure that every participant’s priorities are known. While designing the questionnaire that underlies the Delphi method may be particularly challenging for complex topics or stakeholder groups who are unfamiliar with the research topic or process, three studies15,33,56 reported using this technique with patients, public, or caregivers. Two of the three Delphi studies of consumers reported high response rates with each round (range from 78 percent to 90 percent),15,33 with the largest study reporting a 44 percent response rate.56 In this study, the participants had difficulty rating research priorities to identify future research in hospice care for children.

A related but shorter method involved questionnaires that used rankings and/or frequencies for respondents rating survey items using a Likert or other scale.8–10,12,18–20,22,53,55 Among the 10 studies that used this method, 4 involved the public, patients, or caregivers.8,12,18,53 In this context, the electronic or paper-based questionnaires were either administered alone or in the context of citizens’ juriesor workshops. Finally, questionnaires were commonly chosen by studies aimed at engaging expert researchers or clinicians.8–10,20,51,53–55

Four studies used a nominal group technique during which members of a group individually listed all their ideas, usually on a piece of paper.27,28,30,52 A facilitator asked each person to explain their ideas to the group and address any questions. The group then voted on a ranking of the ideas. The point of the nominal group was to ensure that each individual participated and had a voice. This method retained some of the benefits of focus groups, such as being able to provide more in-depth context of the research topic(s) to resolve possible confusion while also providing a mechanism to count every view.

Overall, a mixed methodological approach19 may be optimal because the in-person discussions allow for explanations and clarification of concepts, while questionnaires, Delphi, or voting allow for quantitative analysis (either totals for all individuals or weighted for groupings). The Institute of Medicine (IOM) used a process to develop national priorities for comparative effectiveness research that may be particularly informative regarding the use of mixed methodological approaches.31 It created a multidisciplinary committee comprised of health care providers, researchers, consumer advocates, an insurer, and one health system representative. The committee identified relevant groups of stakeholders a priori: (1) consumer/patient/advocacy groups; (2) Federal government agencies; (3) health care providers and researchers; (4) insurers; (5) integrated health systems; (6) manufacturers; and (7) state government agencies. They posted all announcements for in-person meetings on the IOM Web site and distributed by electronic mail to general IOM lists, including 20,000 mailings and held a one-day meeting during which 54 stakeholders gave 3- to 5-minute presentations about setting research priorities to the committee and a public audience. The distribution of speakers represented diverse stakeholder groups, with 56 percent health care providers and researchers, 18 percent consumers, 15 percent manufacturers, 6 percent insurers, and 4 percent Federal or state government agencies. Following these presentations and discussions, a Web-based questionnaire was distributed via e-mail and public postings (including Web posting) to generate a list of priorities. The committee considered input from all venues in their final decisionmaking.

#### Assessing the Representativeness of Stakeholder Involvement

Failure to recruit a representative sample of stakeholders introduces potential bias and reduces confidence in reliability of results. One potential method to assess representativeness is through participation or response rates. Among the 56 studies that engaged stakeholders to prioritize research, fewer than one-third of studies reported this level of detail.8,10,15,16,20,32,33,37,40,41,50,53,56,57,59 As shown in Appendix H, participation rates ranged from a low of zero (of 20 contacted) for a workshop of consumers designed to understand barriers in developing public health research32 to a high of 100 percent in a Delphi study of caregivers to identify mental health research priorities by stakeholder groups.33 Because the number of studies that provided these data were few, it was not possible to identify a clear association between engagement methods and response rates.

Response rates may not provide an accurate reflection of representation. For example, response rates do not accurately address representativeness of populations if the stakeholders who were initially recruited were not representative to begin with. Furthermore, for studies such as the IOM report that advertises through Web sites, it is difficult to know the total number of people that were reached (the denominator) in order to calculate the response rate.31 For such studies, comparing the intended (a priori) list of stakeholders to the actual proportion of stakeholders engaged may be a more meaningful measure. While no gold standard currently exists, reporting the details of stakeholders engaged for each step provides the reader with a method to evaluate overall representation.

#### Unanswered Questions

There are considerations for analysis of stakeholder feedback that have not been resolved by the literature. For example, is it important to know that every individual had a voice in determining the final priorities? Additionally, and especially when multiple stakeholder groups are involved, should priorities be based upon an equal weighting of all participating individuals votes, or should the results be unequally weighted by stakeholder group, organization, or other factor? Commonly, studies report consensus without knowing explicitly the contributions of the individuals. Others, whether questionnaire (single or Delphi) or voting, counted every individual and presented overall results.

In summary, important considerations for stakeholder engagement include the intended purpose of engagement, the explicit identification of stakeholder groups, the distribution of the constituency (i.e., equal participation by group compared with other), the complexity of the topic, and the nature of the feedback that investigators want to see. Important considerations for analysis include the most appropriate way to present the data. Should stakeholder responses be presented in aggregate or averaged? Should the responses be presented for all stakeholders who were engaged or should they be stratified by stakeholder group? These considerations, in addition to resources and time available, will largely determine the optimal approach.

## Phase 2: Key Informant Interviews

We conducted a series of interviews with a broad range of KIs to identify important issues and elicit recommendations for engaging stakeholders and analyzing stakeholder input. Twenty individuals were contacted for interviews and ultimately, 13 semistructured telephone interviews were conducted with 15 KIs in the United States, Canada, and the United Kingdom (75 percent participation rate). KIs were from academic institutions, practice-based research networks, nonprofit organizations and other organizations devoted to health care issues on local and national levels in the United States, Canada, and Europe. Each interview lasted up to one hour. Of the 13 interviews, 11 were conducted with KIs who had experience engaging stakeholders to identify and/or prioritize future research. In the two other interviews, stakeholders were engaged for other purposes, including allocation of health care resources and implementation of public health programs and policies (Figure 3).

Figure 3 Key informants invited and interviewed

KIs were selected for their experience engaging a broad range of stakeholders including consumers, clinicians, policymakers, researchers, research funders, insurers/payers, and/or manufacturers (Table 5).

Table 5 Key informant interviews: Stakeholder groups engaged by KIs

Key Informant Interview | Consumers | Clinicians | Policymakers | Manufacturers | Research Funders | Researchers
1 | | | ● | | | ●
2 | ● | ● | ● | | | ●
3 | ● | | ● | | | ●
4 | | | ● | | | ●
5 | ● | ● | ● | | ● | ●
6 | ●
7 | ● | ● | ● | | | ●
8 | | ● | ● | ● | | ●
9 | | ● | ● | | ● | ●
10 | ● | ● | ●
11 | ● | ● | | | ● | ●
12 | | | ● | | ● | ●
13 | ● | ● | | | | ●

### Defining Stakeholders

Even among individuals with extensive experience engaging stakeholders, stakeholder terminology was unclear or inconsistently applied. The interviews emphasized the lack of consistency and clarity in this process. Examples are provided below:

Unclear Terminology | “When we started the project, we had to define who the stakeholder was . . . and that in itself really proved to be quite challenging.” (KI interview 4) “…when you say ‘stakeholders,’ you’re talking about anybody who will benefit from….the research or from the evidence…am I understanding your definition of stakeholder?” (KI interview 6)
Clear categorization is important | “There’s opportunity for public comment. Number one, public input is the term that we use, but with respect to the highly technical stuff that we do, it’s a misnomer. Public input is industry input.” (KI interview 7)

### Recruitment

Interview Highlights

- The media and Internet/Web can be used to recruit consumers.
- Leveraging existing contacts is frequently used and effective.
- For some situations, stakeholder recruitment depends on establishing relationships, building connections, and networking.
- It is useful to begin with a broad list of potentially relevant stakeholder groups.
- Assign staff with strong communication skills to engage in recruitment activities.
- Recruit individuals who are passionate about the research topic.
- Cold calling is a concept from business that may be used to recruit stakeholders in health research.
- Caller identification makes cold calling a recruitment challenge.
- Special consideration should be given to the cost of mailing letters and the high return rate for incorrect addresses.
- Followup is essential.

KIs recommended recruiting individuals who are passionate about the research topic to facilitate the recruitment and engagement process. They emphasized that recruiting these individuals helps to ensure that stakeholders will remain engaged throughout the research prioritization process. KIs used several methods to recruit stakeholders that differed according to topic, organization, and the stakeholder groups engaged. Often, researchers recruited multiple groups of stakeholders for engagement. Contacting stakeholders by phone or e-mail was common. One KI commented on the importance of the personality of the person responsible for calling when using cold calls as a recruitment strategy:

“In fact, I hired a college student to cold call every practice . . . and he was this young pre-med student, and he had a nice winsome voice…How could you say no to that guy? …everybody said, ‘Yes.’” (KI interview 11)

Another KI recommended using letters for consumer engagement even though only 30 percent to 40 percent of the letters sent were returned. One KI asked consumers if they would be more likely to respond to a mailed letter or a call when contacted by unknown individuals. Consumer participants reported that they would be more likely to respond to a letter than a cold call, and several said they would never respond to a cold call (one stated that they used caller identification to avoid answering a call from an unknown source).

An additional challenge to stakeholder recruitment was that the stakeholder identified and initially contacted may refer the project to another individual who does not have the desired characteristics or is not representative of the target stakeholder group. KIs cautioned to be mindful that this could occur and that the intended perspective may not be maintained.

“So we would invite [policymakers], and they would either ignore it or they would [refer us] to somebody lower in the hierarchy. We would end up with a midlevel decisionmaker who’s less likely to have influence over policy than the person we invited.” (KI interview 12)

KIs suggested that a variety of strategies may need to be employed simultaneously to recruit stakeholders:

“…[when] we had a specific contact, we would reach out by e-mail. In some cases we sent letters to organizations. We did a lot of essentially cold calling with organizations where we didn’t have a contact, where we would call the organization’s general number, and try to work our way through to an appropriate contact for our project.” (KI13)

### Engagement

Interview Highlights

Methods used for stakeholder engagement include:

- In-person meetings (one-to-one meetings, advisory committee, public forums, and focus groups)
- Telephone interviews, conference calls
- Webinars, e-mail
- Citizens’ juries
- Questionnaire: online
- Modified Delphi technique
- Mixed methods (for example, in-person meetings and electronic questionnaires).

KIs engaged stakeholders using a variety of methods, including e-mail, conference calls or Webinars, focus groups, citizens’ juries, workshops conferences, and the modified Delphi technique, and often used multiple methods (mixed methods) to engage the same stakeholder groups. (A description of engagement methods is provided in Appendix F.) The two most common methods that were used by KIs to engage stakeholders were one-to-one meetings (in person or by phone) and working group/committee/council meetings. According to KIs, the advantages of in-person meetings included: (1) ensuring a time of focused stakeholder attention to the subject, (2) fostering relationships among stakeholders, and (3) promoting a better understanding of the each other’s needs and priorities through discussion. One KI commented:

“… people know they have materials to review, but they only understand it to the extent of …the time available. When they’re brought together and have blocked off time to actually focus on the questions and discussion, they absolutely shift [their priorities].” (KI interview 13)

KIs reported that one-to-one telephone interviews, e-mail, and conference calls were particularly useful for engaging stakeholders who were geographically dispersed or whose schedules were very busy.

#### Specific Considerations for Stakeholder Engagement

KIs identified strategies that were particularly useful when engaging policymakers, clinicians, and consumers. Strategies varied based on the context of the situation, the dynamics of the relationship, and whether the researcher and stakeholder had a previous relationship.

Clinicians. KIs used one-to-one meetings, e-mail, conference calls, committee meetings, and conferences to engage clinicians. Several KIs indicated that when engaging this group, it was important to be sensitive to the time constraints of their clinical responsibilities and to use flexible methods of engagement. One KI noted that the method of engagement that works best for clinicians depends on their practice:

“…trying to get every major health care professional in the practice in the same room at the same time is quite challenging. So we’ve learned to try other methods…where people can provide input by e-mail, react to memos, and even have Webinars or conference calls, as ways to try to elicit that input.” (KI interview 8)

When initially engaging clinicians, one KI recommended that individuals with a similar level of training or a similar role should engage the target stakeholder (i.e., doctor:doctor or nurse:nurse) and commented:

“But it requires that first step of relationship building, between two people. And frequently, if the clinic is run by a doctor, it requires another doctor.” (KI interview 11)

One KI noted that a common mistake that researchers make is not engaging frontline clinicians as stakeholders. Several KIs felt that frontline clinicians were instrumental in setting research priorities because they are involved in the day-to-day operations and can identify key questions that need to be asked. In addition, engaging frontline clinicians in research prioritization processes was considered essential to creating a meaningful, focused research agenda with the potential to achieve “pivotal” changes in health care practice. One KI stated that failing to include such stakeholders could result in wasting precious resources on the wrong research question.

“A common mistake we certainly made is not engaging the clinicians themselves in the practices, as stakeholders… with top down [organizations] there’s this real risk of the agenda being driven by the people that run the [organization] or even by the funders that support the [organization]. And the frontline clinicians in the practices where the research is supposed to be conducted are not involved in identifying questions…or eliciting buy-in…and that’s a huge mistake. For one thing, you miss the opportunity to identify really key questions for the research to address.” (KI interview 8)

Consumers. Although the methods that KIs used to engage consumers was similar to that of other stakeholder groups, consumers’ motivations and needs as stakeholders were viewed quite differently. KIs noted that consumers were focused on identifying research that addressed their personal health care needs and the needs of their communities. In contrast to policymakers and clinicians, KIs reported that it takes a substantial amount of time to engage consumers because they are unfamiliar with the research process and/or research topics. Several KIs warned that often researchers underestimate the duration of time, patience, and attentiveness required. One KI commented:

“And the reality is that if a researcher will take the time…, and that’s extremely important, ask the questions, nurture a relationship, and patiently listen, that the community is very happy to engage and participate.” (KI interview 6)

KIs reported that consumers can be intimidated by the language of research, protocols, and Institutional Review Boards. They need guidance, patience, and the opportunity to ask questions about the technical aspects of the research and research topics to overcome initial apprehension. They also mentioned difficulties in obtaining the intended stakeholder during recruitment.

“It’s a real challenge to get the right sort of patient representative… someone who isn’t intimidated by…the technical and scientific discussion, and is comfortable…voicing their opinion…our target population is often pretty sick…[but] what we’re getting is someone who’s at the healthier and more educated, and more health literate end of our patient population.” (KI interview 9)

We found considerable variation in the value KIs placed on involving consumers in their research prioritization processes. Some KIs excluded consumers or dismissed their contributions because they lacked research experience, scientific knowledge, or technical expertise to meaningfully contribute to health care discussions or setting a research agenda. In contrast, other KIs advocated strongly for their inclusion and noted that they provided critical contributions to a research agenda that represented the needs of consumers and reflected health care issues commonly faced by their communities. They felt that consumers were not only capable of understanding the research process, but they also made important contributions during topic identification, study design, and manuscript preparation.

Policymakers. KIs preferred to either engage policymakers by phone, with one-to-one interviews, or in small meetings. Two KIs stressed the importance of having “off-the-record” discussions with policymakers so that they felt comfortable asking questions about research without representing a specific constituency or agency. Several KIs mentioned that it is important to understand the pressing time demands that these policymakers encounter on a daily basis.

Researchers. KIs found that engaging researchers as stakeholders can be challenging because though they are familiar with this process, they may not be accustomed to this type of collaboration. A KI commented,

“One of the challenges is to merge the interest of academic researchers with those of the other stakeholder groups in a way that everybody gets something that they need out of it.” (KI interview 5)

KIs suggested using a skilled facilitator and/or qualitative researchers to facilitate discussions and address issues of dominance (i.e., when conducting focus groups).

### Prioritization

Interview Highlights

- Quantitative methods such as voting, Delphi, and ranking were often used to determine priorities.
- KIs felt that prioritization occurred naturally through discussion within a long-term relationship.
- Stakeholders may need information on resources or feasibility to advise on research prioritization.
- Multiple criteria are used to prioritize research: burden of disease, funding availability, and policy shelf life.

KIs used prioritization processes and criteria presented in Table 6. They used little or no formal process to a structured, formal prioritization process that consisted of multiple rounds of voting/ranking, with at least one vote occurring in person. One KI commented:

“I’m not sure I could define a process…we’re struggling to [develop] something that’s researchable in a way that is useful to the policymaker” (KI interview 12).

Table 6 Key informant interviews: Prioritization methods and criteria

Purpose of Engagement | Key Informant Interview Number^a^ | Frequency of Engagement | Prioritization Method | Prioritization Criteria
Identify research topics for reviews to inform policy | 1 | Ongoing (once yearly) | Two voting sessions: One vote during e-mail/online followed by multiple votes in person | Policy “shelf life” and interest Enough evidence to inform review
Identify research topics for reviews to inform policy | 4 | Ongoing (frequency not stated) | Two voting sessions: One vote during e-mail/online followed by multiple votes in person | Policy “shelf life” and interest Enough evidence to inform review
Set research priorities for organization | 5 | Ongoing (once yearly) | Consensus (in person discussion) If no consensus, vote | Funding opportunities
Set research priorities for organization | 6 | Ongoing (frequency not stated) | Consensus (in person discussion) | Burden of disease Resonance with community Funding opportunities
Set research priorities and identify topics for systematic reviews | 8 | Ongoing (frequency not stated) | None described | Potential for policy/clinical practice change
Identify research priorities | 9 | Ongoing (frequency not stated) | Consensus (in person discussion) Experimenting with interactive analytic feedback model | Disease burden Quality of care gaps (known) Potential of research to improve health outcomes or clinical practice Cost
Identify research topics for evidence/systematic reviews | 10 | Ongoing (approximately once every two years) | Specialized area/topics: Multiple votes (in person) Broader topics: Modified Delphi | Cost of research Current resources
Set research priorities for organization | 11 | Ongoing (not stated) | Consensus (in person) | Feasibility (need resources to carry out) Disease burden Funding opportunities
Prioritize a research agenda | 13 | Single | Online ranking followed by in person ranking (audience response) | No specific criteria

a For two key informant interviews, future research was identified, but not prioritized. In two other interviews, key informants did not identify or prioritize research.

KIs often used an initial voting/ranking process to limit the number of research topics discussed and prioritized at a subsequent in-person meeting. They noted that having the opportunity to eliminate research topics from a broad list prior to the meeting offered several advantages, including: (1) a pared-down list of research topics allowed staff to provide detailed materials on the research topics that were being prioritized, and (2) the work of the stakeholders during the day of the meeting was made easier because they could focus on the most important items for voting and ranking. In one interview, KIs described using an audience response system to elicit stakeholder input at an in-person meeting, which proved particularly helpful in eliciting the priorities of all stakeholder attendees. By using this tool, they felt that they heard and recorded all stakeholders’ research priorities. A KI commented:

“We had two clinical experts who were part of our project team. They helped us to conduct a literature review and identify a comprehensive set of potential research questions. We took that set of research questions out to the technical working group…brought them together as a group on a conference call, to discuss it, and then sent them…an online ranking tool…where they ranked the questions.... We gathered the information from that ranking process, and then brought them together to the in-person meeting where they talked about the ranking, and they discussed their views that were driving their…selection of the priorities…that’s how we came to our final list of research questions.” (KI interview 13)

Finally, while formal quantitative methods were helpful for arriving at a prioritized list, KIs also felt there was value to in-person meetings in this process:

“The difference wasn’t so much in the completion of the [voting/ranking], but in your ability to explain the questions…because the research questions to be prioritized can be read, in different ways, depending on how they’re worded…So being able to explain it was beneficial. I think we got more accurate impressions when people were actually in person.” (KI interview 13)

#### Criteria Used To Prioritize Research

KIs reported that stakeholders used multiple criteria to prioritize research including funding availability, current resources available, the burden of disease, community resonance, policy “shelf life,” and in the case of systematic reviews, having adequate primary research to conduct a systematic review (Table 6).

One KI described an innovative approach applying prioritization criteria using an interactive analytic feedback model. Stakeholders were able to make adjustments using different prioritization criteria and compare the potential impact of multiple research projects on each criterion (i.e., burden of disease, cost of treatment, and potential maximum impact of intervention/quality initiative are included in the model).

“We’ve actually have been experimenting with…a decisionmaking model in working with stakeholders to help them look at that process, and so they can punch in some numbers…and they can show how much impact that would have on health outcomes…

The model could say, ‘Given the number of strokes, given the effectiveness of thrombolysis, if we got it from 10 to 20 percent, here’s how many [persons] would be affected, and here’s how much it would help outcomes.’ And then [the stakeholder] could say, ‘All right, well how about preventing stroke?’

“We’ve found that to be very helpful in testing people’s gut assumptions about what the highest priorities are to work on. Then plugging some of those numbers into a model, and then feeding that information back to the people, was very helpful in shaping the discussion about where the priorities ought to be.” (KI interview 9)

### Considerations in Working with Stakeholders

Regardless of the method used to engage stakeholders, KIs emphasized that leveraging contacts, establishing long-term partnerships, and building trust and credibility were critical.

Interview Highlights

Barriers to Stakeholder Engagement

- Lack of time on the part of stakeholders (busy)
- Lack of release time and compensation for members of the public
- Researcher need for quick response (timeframe too short for community to weigh in)
- Stakeholder needs not met in previous engagement

Factors in Successful Engagement

- Engage stakeholders early in the process
- Prior to engagement, clearly detail expectations (e.g., anticipated commitment of time and types of activities)
- Maintaining ongoing relationships is important to building trust and credibility
- Provide opportunities for people to ask questions before meetings (particularly for consumers or others who are unfamiliar with research)
- Premeeting information materials promote comfort with the topic and enable informed discussion
- Premeeting “icebreakers,” especially when engaging stakeholders with differing experiences/perspectives
- Having someone with similar training to the stakeholder can be helpful—particularly thought to be important for clinicians
- No stakeholder’s comment is considered superior or inferior to another perspective
- Followup presentation of results is important to stakeholders
- Be clear about the stakeholder role—do not expect community members to do academic duties
- Be sensitive to the time constraints of all stakeholders

Facilitators Can Be Useful For Stakeholder Engagement

- Trained/neutral facilitator encourages participation and focuses discussion at in-person meetings
- Facilitator knowledgeable of various stakeholder environments (cultural understanding)
- Skilled facilitator ensures all stakeholders are heard and manages dominance issues

Bringing diverse stakeholders together may require as much attention to group dynamics as to the presentation of research topics and prioritization criteria, which may be an unaccustomed concern for some researchers:

“It’s been a huge learning curve for everybody. And I think, at this point, we work really well together, and we’ve got it down, but it was a struggle in the very beginning. The culture of [researchers] is very different than a state policymaker who’s being called in front of a public committee next week and needs an answer. And it took us a while to sort of get to the middle, where everybody understood each other’s perspectives, and the thing that I will say that we have learned time and again, and has serves us really well, is that we pay a lot of attention to process.” (KI interview 10)

#### Barriers to Stakeholder Engagement

KIs described several challenges they encountered when they engaged stakeholders, and offered advice for navigating these issues. Several KIs reported that stakeholders’ busy schedules and competing demands for their time are common, and having flexible engagement methods can help to ensure that critical stakeholders are engaged. In addition, KIs commented that individuals frequently encounter both logistic and financial barriers to providing input as stakeholders. One KI mentioned that some individuals have difficulty getting time off from work. Two KIs mentioned that the geographic dispersion of stakeholders made engaging individuals who were representative of stakeholder groups difficult and recommended paying for their travel and compensating them for missed time from work. KIs recommended limiting the frequency of travel required of stakeholders by using interim engagement methods such as Webinars, conference calls, and e-mail. Limited resources, including staff, made it difficult to engage all of the stakeholder groups that they targeted a priori and made it difficult to maintain relationships over time. The latter was felt to be particularly challenging since KIs reported that it takes time to establish credibility with stakeholders.

#### Factors in Stakeholder Engagement

KIs mentioned several strategies for stakeholder engagement. Nearly all KIs emphasized that the key to establishing credibility and engagement of stakeholders for future research prioritization is to establish trust and facilitate ongoing, long-term relationships with stakeholders. Especially for consumers and others who were unfamiliar with the topic, providing pre-meeting materials that were easily understood by nonexperts and/or providing opportunities for the stakeholders to ask questions before the meeting were noted to be helpful to group meetings. Pre-meeting “icebreaker” sessions were also thought to be helpful when conducting in-person meetings with multiple stakeholders with different expertise or experiences (i.e., policymakers, clinicians, and consumers). They noted that these pre-meeting opportunities also helped the KI team target important topic areas that they may have otherwise overlooked. Lastly, KIs reported that a good facilitator was an important feature of group meetings. The facilitator was helpful in ensuring that meetings stayed on track and that one stakeholder’s agenda did not dominate the meeting.

KIs offered the following advice to foster stakeholder relationships:

Engage stakeholders early | “One of the mistakes is to circle back to them well into the project for input…and then you get the message from them: Well, if you really had wanted to study this, you should have done this completely differently. Come to them at the very beginning with the first sparkle of the idea, and start getting their reactions.” (KI interview 8)
Finding common ground | “One of the challenges is to merge the interest of academic researchers with those of the other stakeholder groups in a way that everybody gets something that they need out of the interaction.” (KI interview 5)
Partnership | “…community engagement is a lot like a marriage…if it’s a long-term relationship…you start having to prioritize stuff. But most of it’s not explicit…It’s that you’re in a relationship with someone. And the relationship bounces that back and forth, all the time, and it’s ongoing.” (KI interview 11)
Understanding needs | “It’s trying to reach common ground through the research. It’s really working hard to understand what it is the policymakers needs are, and then…helping to translate that into a research question, or set of research questions that are really answerable requires a back and forth. So each person, coming to a better understanding of the other’s world, and what’s possible in both environments.” (KI interview 12)
Respect | “It’s very important to convey a sense of respect for both their knowledge and their time in contributing to the research. I think people react differently if they feel like their views and time is valued.” (KI interview 8)
Trust | “People really respect each other, trust each other, and are very forthright and feel very comfortable talking, expressing their views, disagreeing, and it’s a very nice dynamic. There isn’t any holding back or any feeling of disparagement for disagreeing with somebody else.”(KI interview 4)
Commitment | “What’s really important is how the researcher approaches a community group…this idea of time and commitment and patience is really important…more and more with community engagement…It’s not just this: a couple of focus meetings and I’ll get the information I want, and I’m on my way. That’s not going to work. You better be committed to me for as long as this project’s lasts, and maybe longer, and be as willing to become interested and committed to this community as I am.” (KI interview 6)

## Phase 3: EPC Interviews

### Review of Protocols

We reviewed the EPC future research pilot protocols and found that EPCs proposed a range of approaches to engaging stakeholders, as described in Appendix I. Included among these approaches were two who intended to engage the support of the Effective Health Care Scientific Resource Center and two who intended to work with the Eisenberg Center in engaging stakeholders. Most centers intended to use group calls, with two EPCs using a formal Delphi process.

### Semistructured Discussions with EPC Directors and Staff

We interviewed representatives from eight EPCs regarding their experiences engaging stakeholders during their future research needs pilot projects. Although these pilot projects were intended to develop and compare a range of approaches to developing future research needs documents, the EPCs had remarkably similar experiences and methods for engaging stakeholders. A defining feature associated with reporting fewer challenges in engaging stakeholders was the currency of the report itself. Reports published more recently and/or by the EPC doing the future research had a natural constituency from which to draw potential stakeholder members. These teams generally drew upon the investigators and Technical Expert Panel (TEP) from the original report to participate in or suggest other individuals for the stakeholder group.

The EPCs were interested in discussing the appropriate role for and strategic goal for engaging stakeholders in a research gaps process. They noted that although gathering input from stakeholders is one purpose, the two-way relationship means that the process could also be an opportunity to influence stakeholder sensitivity to issues raised through identification and prioritization of research needs.

### Stakeholder Constituencies

EPCs included between 6 and 30 stakeholders for their research gaps pilot projects. Target groups for stakeholder engagement included primary researchers, methodologists, patient/consumer advocates, policymakers, funders, payers, industry (for devices), and patients themselves. Of these, all EPCs targeted active researchers, with representation from the other groups varying. One EPC had three distinct stakeholder groups: authors of the report, a group of local experts from their institution (considered internal) and a group of stakeholders outside of their institution (external).

All EPCs considered their stakeholder panels to be well balanced in terms of representing different constituencies. However, several questioned how “representative” should be defined, absent empirical evidence about numbers and breadth of stakeholders required for optimal input. Four of the EPCs noted that their expertise was in the conduct of systematic reviews and not as facilitators or qualitative researchers, suggesting that engagement of stakeholders in the future research needs work was fairly far afield from their usual activities and that they would welcome guidance on the process. The Effective Health Care Program has since released a Stakeholder Engagement Curriculum and Facilitation Primer, both available on the program’s internal Web site.

Several EPCs identified barriers to engaging funders, particularly Federal funders. EPCs reported that the need for high levels of clearance/approval for individuals to participate was ultimately time prohibitive. In part, several suggested that the agencies they were trying to engage were unaware of the project and that it could be helpful to have agency-to-agency communication, or to have the task order officer cosign letters of inquiry. One EPC reported that extramural scientists at the National Institutes of Health (NIH) told them that permission to participate would take too long, while intramural scientists indicated that it would be inappropriate to participate as it would constitute giving advice to researchers. The three EPCs that engaged funders noted that although there was early concern that combining funders and researchers in this process might stifle conversation, this concern did not play out in practice. Perceived barriers in the process may very well be due to the pilot nature of the work, and may be eliminated as the EPCs gain more experience. All EPCs discussed the question of whether and how to engage patients or consumers in the process of identifying research gaps and future research needs. Two of the EPCs felt strongly that patients did not have a role in this particular process, one felt strongly that the patient participation in their project changed the outcome in a positive way, and the remainder were unsure about whether patients should be included. All EPCs felt that patients should be included as stakeholders in other EPC processes; however, they questioned whether patients would contribute to identifying and specifying research gaps. In part, this may be due to the focus of at least two EPCs on methodological research gaps, rather than content areas. Two EPCs questioned their ability to most effectively engage patient stakeholders and expressed concern about ensuring that patients have a positive experience in making their contributions to the process. Certainly the questions of when and how to engage patients are ones that warrant further conversation among the EPCs, and guidance from AHRQ, some of which is now available through materials published by the Effective Health Care Program on methods for stakeholder engagement. One EPC chose to include a “proxy” for the patient perspective and involved an individual who worked closely with patients on a daily basis.

Those EPCs that did support the involvement of patients and consumers in this particular process also noted the need to find the right person and to manage the relationship in such a way as to maximize involvement and ensure that the patient voice was heard. One important challenge is determining whether this is best accomplished with an individual patient or a patient advocacy group, in which case the representative may or may not be a patient.

### Methods for Identifying Stakeholders

All EPCs used a combination of approaches for identifying potential stakeholders, most of which began with individuals who were known to the EPC investigators, either because they were involved in the report for which future research recommendations were being developed or through professional relationships. The selection of stakeholders was not random, but based primarily on availability and convenience, knowledge, and personal contacts. EPCs uniformly looked to individuals who had been involved in the original review, such as TEP members or peer reviewers, suggesting that for continuing the process of developing separate future research documents, the EPC program might envision a more extended role for TEP members and/or peer reviewers. If this does occur, it will be important to ensure that these individuals understand the extended nature of their role, which may include participation during the development of a future research needs document that follows preparation of the comparative effectiveness review itself.

### Processes for Gathering Stakeholder Input

Details of the processes used to gather stakeholder input are available in the full reports developed by each EPC and are available on the AHRQ Effective Health Care Web site (available at: www.effectivehealthcare.ahrq.gov). EPCs most commonly used group conference calls along with e-mail or Web-based prioritization, and one presented a Webinar to bring stakeholders up to speed. The number and types of contacts that occurred with stakeholders varied, including letters, one-to-one orientation calls, group calls, survey tools, e-mails, and Webinars. Several stressed the importance of being flexible to meet the stakeholders’ communication needs. For example, two EPCs invited stakeholders to choose whether they would like to contribute via phone or electronically, with the most popular choice being electronic communication or prioritization. Another EPC noted that calls were scheduled outside of work hours to accommodate busy schedules. Taken together, these observations may indicate that some stakeholders find it challenging to provide adequate time during the workday to contribute and prefer times to participate outside of work, as well as methods that they can access on their own timeframe.

### Challenges Identified

EPCs routinely identified three main challenges:

1. Timing: The requirement that the project take place very quickly and over the summer made it difficult to coordinate schedules and likely resulted in an inability to engage some stakeholders. This was particularly true of academic researchers engaged as stakeholders.
2. Restriction on number of stakeholders: Engaging more than nine nonfederal citizens with a structured survey on behalf of the United States Government would require a lengthy clearance process through the Office and Management and Budget. The time needed to obtain this clearance was prohibitive to timely completion of this project, so the number of stakeholders engaged was kept to nine or less. This limited number was generally perceived as too few to capture the breadth of views of researchers and patients necessary for identifying research gaps.
3. Engaging Federal partners: The difficulty in engaging Federal stakeholders, primarily at the NIH, was due primarily to the need for permissions that took too long to obtain and resulted in several EPCs not including NIH representatives.

#### Value of Stakeholder Involvement

Six of eight EPCs considered the involvement of stakeholders to be of value in identifying research gaps, with caveats noted above about being able to engage too few stakeholders and questions about whether the group was appropriately representative. Some emphasized the value of engaging individuals involved in primary research for understanding gaps, methodological challenges, and implications of recommending certain avenues for research. Stakeholders were noted to have identified previously unrecognized areas of importance, and also were helpful in reframing or rephrasing specific questions to make them more concise and clear. One stakeholder noted that no matter how much internal expertise the EPCs have, there will always be additional information or perspectives to be gained from including stakeholders.

### EPC Lessons Learned

We asked EPCs to make recommendations or describe lessons learned that might help the Effective Health Care Program optimize the use of stakeholders in identification of research gaps and future research needs. Across all EPCs, the lessons learned and recommendations made were remarkably consistent.

1. The EPCs would welcome input on achieving an optimal balance of stakeholders, including target numbers of stakeholders. Three EPCs noted specifically that nine stakeholders is too few and that especially with a small number of stakeholders, one or two voices can have undue influence on the project. Even with a small number, scheduling busy people can be unduly difficult to get the work done in a short time period. Conversely, too many stakeholders can lead to an unwieldy process that does not produce actionable results. Related to this is the need to explicitly describe the strategic goal intended in engaging stakeholders.
2. Along these lines, EPCs noted that the process of identifying, contacting, and bringing stakeholders on board takes longer than anticipated in the protocols. It would be helpful to have a realistic assessment of the timeline for this activity based on the experience of the EPCs to date. The Effective Health Care Scientific Resource Center might also provide some guidance on how much time to allot for engaging stakeholders.
3. Assistance in engaging individuals from Federal agencies is requested from AHRQ. One specific suggestion was that AHRQ task order officers cosign initial letters of inquiry. EPCs also noted that as an increasing number of projects are done using stakeholders, it will be important to ensure that multiple EPCs are not unduly tasking the same individuals or groups.
4. The role of patients and patient advocates on identifying research gaps and specifying future research warrants discussion by EPC leadership. It was noted that for some projects—especially those with a strong methodological focus—patient participation may not be appropriate. When the patient or consumer voice is needed, EPCs recommended budgeting additional process time and effort to make sure that these individuals are oriented to the project and that their input is heard and assimilated.
5. EPCs and AHRQ should communicate clearly with the stakeholders about the trajectory of the work, both in terms of timeline and likely number of hours anticipated for the project. For example, for several EPCs, the stakeholder involvement was concentrated during a particular phase of the project. If an option going forward is to have TEP members continue with the Future Research process, they should be informed of this extended opportunity for participation including the timeline and likely effort involved. Clear instructions and documentation about the role of a stakeholder would be helpful, and ideally would be developed for the Effective Health Care program as a whole to increase consistency.
6. As EPCs increase their work in a particular clinical concentration, they are likely to build relationships with certain stakeholders and identify stakeholders that are particularly helpful at identifying research gaps. EPCs see this as a benefit; however, they note that stakeholder fatigue could be an issue if these same individuals are approached too frequently.
7. Three EPCs noted it might have been helpful to compensate stakeholders engaged in the future research needs pilot projects. (Under AHRQ policy, compensation is allowable but not required.)
8. Each KI received conflict of interest disclosure instructions and an EPC disclosure form to complete prior to being interviewed by Oregon EPC investigators. For future activities, it would be helpful to add definitions of KIs and stakeholders to the disclosure instructions and edit the form to include KIs and stakeholders. As EPCs continue to engage stakeholders for developing research questions, refining methods, identifying research gaps, and prioritizing research needs, these changes are important to clearly identify the nature of the input that we are seeking and avoid confusion about the expected roles of KIs and stakeholders.