# References

1 Institute of Medicine. (2009). Initial National Priorities for Comparative Effectiveness Research.
2 Federal Coordinating Council for Comparative Effectiveness Research. (2009). Report to the President and the Congress.
3 Tunis SR, Stryer DB, Clancy CM. (2003). Practical clinical trials: increasing the value of clinical research for decision making in clinical and health policy. JAMA.
4 Stanley K. (2009). Exploring impact: Public involvement in NHS, public health and social care research.
5 Hickam D, Gordon C, Curtis P, et al. (2009). AHRQ Effective Health Care Program Evidence-based Practice Centers Assessment.
6 Jinks C, Ong BN, O’Neill TJ. (2009). The Keele community knee pain forum: action research to engage with stakeholders about the prevention of knee pain and disability. BMC MusculoskeletDisord.
7 Niner S, Pirkis J, Krysinska K, et al. (2009). Research priorities in suicide prevention: a qualitative study of stakeholders’ views. Australian e-Journal for the Advancement of Mental Health.
8 Griffiths KM, Jorm AF, Christensen H, et al. (2002). Research priorities in mental health, Part 2: an evaluation of the current research effort against stakeholders’ priorities. Aust N Z J Psychiatry.
9 Gould N, Huxley P, Tew J. (2007). Finding a direction for social research in mental health: establishing priorities and developing capacity. J Soc Work.
10 Sharan P, Gallo C, Gureje O, et al. (2009). Mental health research priorities in low- and middle-income countries of Africa, Asia, Latin America and the Caribbean. Br J Psychiatry.
11 Sibbald SL, Singer PA, Upshur R, et al. (2009). Priority setting: what constitutes success? A conceptual framework for successful priority setting. BMC Health Serv Res.
12 Menon D, Stafinski T. (2008). Engaging the public in priority-setting for health technology assessment: findings from a citizens’ jury. Health Expect.
13 Welfare MR, Colligan J, Molyneux S, et al. (2006). The identification of topics for research that are important to people with ulcerative colitis. Eur J Gastroenterol Hepatol.
14 O’Brien K, Wilkins A, Zack E, et al. (2010). Scoping the Field: Identifying Key Research Priorities in HIV and Rehabilitation. AIDS Behav.
15 McIntyre S, Novak I, Cusick A. (2010). Consensus research priorities for cerebral palsy: a Delphi survey of consumers, researchers, and clinicians. Dev Med Child Neurol.
16 Ross F, Smith E, Mackenzie A, et al. (2004). Identifying research priorities in nursing and midwifery service delivery and organisation: a scoping study. Int J Nurs Stud.
17 Herbison P, Hay-Smith J, et al. (2009). Research priorities in urinary incontinence: results from citizens’ juries. BJOG.
18 O’Keefe BM, Kozak NB, Schuller R. (2007). Research priorities in augmentative and alternative communication as identified by people who use AAC and their facilitators. AAC: Augment Altern Commun.
19 Loeb M, Brazil K, Durand P, et al. (2001). Identifying research priorities on infections in older adults: proceedings of an interdisciplinary workshop. BMC Geriatr.
20 Patrick DM, Remple VP, Kendall P, et al. (2006). Needs, gaps and opportunities for infectious disease research in British Columbia: a perspective from population and public health. Can J Public Health.
21 Schur CL, Berk ML, Silver LE, et al. (2009). Connecting The Ivory Tower To Main Street: Setting Research Priorities For Real-World Impact. Health Aff.
22 Tomlinson M, Swartz L, Officer A, et al. (2009). Research priorities for health of people with disabilities: an expert opinion exercise. Lancet.
23 Smith N, Mitton C, Peacock S, et al. (2009). Identifying research priorities for health care priority setting: a collaborative effort between managers and researchers. BMC Health Serv Res.
24 O’Donnell M, Entwistle V. (2004). Consumer involvement in decisions about what health-related research is funded. Health Policy.
25 Tong A, Sainsbury P, Carter SM, et al. (2008). Patients’ priorities for health research: focus group study of patients with chronic kidney disease. Nephrol Dial Transplant.
26 Wright D, Corner J, Hopkinson J, et al. (2006). Listening to the views of people affected by cancer about cancer research: an example of participatory research in setting the cancer research agenda. Health Expect.
27 Dagenais C, Ridde V, Laurendeau MC, et al. (2009). Knowledge translation research in population health: establishing a collaborative research agenda. Health Res Policy Syst.
28 Robotin MC, Jones SC, Biankin AV, et al. (2010). Defining research priorities for pancreatic cancer in Australia: results of a consensus development process. Cancer Causes Control.
29 Brown K, Dyas J, Chahal P, et al. (2006). Discovering the research priorities of people with diabetes in a multicultural community: a focus group study. Br J Gen Pract.
30 Baker PG, Hegney D, Rogers-Clark C, et al. (2004). Planning research in rural and remote areas. Rural Remote Health.
31 Institute of Medicine, Committee on Comparative Effectiveness Research Prioritization. (2009). Initial National Priorities for Comparative Effectiveness Research.
32 Graham J, Broom D, Whittaker A. (2001). Consulting about consulting: challenges to effective consulting about public health research. Health Expect.
33 Owens C, Ley A, Aitken P. (2008). Do different stakeholder groups share mental health research priorities? A four-arm Delphi study. Health Expect.
34 Perkins P, Booth S, Vowler SL, et al. (2008). What are patients’ priorities for palliative care research?—a questionnaire study. Palliat Med.
35 Rose D, Fleischman P, Wykes T. (2008). What are mental health service users’ priorities for research in the UK?. J Ment Health.
36 Hauck Y, Kelly RG, Fenwick J. (2007). Research priorities for parenting and child health: a Delphi study. J Adv Nurs.
37 Butler MM, Meehan TC, Kemple M, et al. (2009). Identifying research priorities for midwifery in Ireland. Midwifery.
38 Malcolm C, Forbat L, Knighting K, et al. (2008). Exploring the experiences and perspectives of families using a children’s hospice and professionals providing hospice care to identify future research priorities for children’s hospice care. Palliat Med.
39 Abma TA. (2006). Patients as partners in a health research agenda setting: the feasibility of a participatory methodology. Eval Health Prof.
40 Caron-Flinterman JF, Broerse JE, Teerling J, et al. (2005). Patients’ priorities concerning health research: the case of asthma and COPD research in the Netherlands. Health Expect.
41 Perkins P, Barclay S, Booth S. (2007). What are patients’ priorities for palliative care research? Focus group study. Palliat Med.
42 Saunders C, Gooden H, Robotin M, et al. (2009). As the bell tolls: a foundation study on pancreatic cancer consumer’s research priorities. BMC Res Notes.
43 Burhansstipanov L. (2005). Community-driven Native American cancer survivors’ quality of life research priorities. J Cancer Educ.
44 Heinemann AW. (2008). State of the science of postacute rehabilitation: setting a research agenda and developing an evidence base for practice and public policy. An introduction. Rehabil Nurs.
45 Kilgore KL, Scherer M, Bobblitt R, et al. (2001). Neuroprosthesis consumers’ forum: consumer priorities for research directions. Journal of Rehabilitation Research & Development.
46 Entwistle V, Calnan M, Dieppe P. (2008). Consumer involvement in setting the health services research agenda: persistent questions of value. J Health Serv Res Policy.
47 Gooberman-Hill R, Horwood J, Calnan M. (2008). Citizens’ juries in planning research priorities: process, engagement and outcome. Health Expect.
48 Rosenstock L, Olenec C, Wagner GR. (1998). The National Occupational Research Agenda: a model of broad stakeholder input into priority setting. Am J Public Health.
49 Crowe JL, Keifer MC, Salazar MK. (2008). Striving to provide opportunities for farm worker community participation in research. J AgricSaf Health.
50 Sprigle S, Cohen L, Davis K. (2007). Establishing seating and wheeled mobility research priorities. Disability & Rehabilitation: Assistive Technology.
51 Buckley B, Grant AM, Firkins L, et al. (2008). Prioritizing incontinence research: patients, carers and clinicians working together. Journal of the Association of Chartered Physiotherapists in Women’s Health.
52 Chalkidou K, Whicher D, Kary W, et al. (2009). Comparative effectiveness research priorities: identifying critical gaps in evidence for clinical and health policy decision making. Int J Technol Assess Health Care.
53 Cohen CI, D’Onofrio A, Larkin L, et al. (1999). A comparison of consumer and provider preferences for research on homeless veterans. Community Mental Health Journal.
54 Kapiriri L, Tomlinson M, Chopra M, et al. (2007). Setting priorities in global child health research investments: addressing values of stakeholders. Croat Med J.
55 Robinson J, Pirkis J, Krysinska K, et al. (2008). Research priorities in suicide prevention in Australia. A comparison of current research efforts and stakeholder-identified priorities. Crisis.
56 Malcolm C, Knighting K, Forbat L, et al. (2009). Prioritization of future research topics for children’s hospice care by its key stakeholders: a Delphi study. Palliat Med.
57 Schopper D, Torres AM, Pereira J, et al. (2000). Setting health priorities in a Swiss canton: what do different methods tell us?. J Epidemiol Community Health.
58 Kellum JA, Mehta RL, Levin A, et al. (2008). Development of a clinical research agenda for acute kidney injury using an international, interdisciplinary, three-step modified Delphi process. Clin J Am Soc Nephrol.
59 Henschke N, Maher CG, Refshauge KM, et al. (2007). Low back pain research priorities: a survey of primary care practitioners. BMC Fam Pract.
60 Yano EM, Bastian LA, Frayne SM, et al. (2006). Toward a VA Women’s Health Research Agenda: setting evidence-based priorities to improve the health and health care of women veterans. J Gen Intern Med.
61 Mendell MJ, Fisk WJ, Kreiss K, et al. (2002). Improving the health of workers in indoor environments: priority research needs for a national occupational research agenda. Am J Public Health.
62 Preskill H, Jones N. (2009). A practical guide for engaging stakeholders in developing evaluation questions.