# Peer Reviewers

Tim Carey, M.D., M.P.H.

Research Triangle Institute/UNC Evidence-based Practice Center

Cecil G. Sheps Center for Health Services Research, University of North Carolina at Chapel Hill

Chapel Hill, North Carolina

Lore Joplin, M.P.A.

Center for Evidence-based Policy, Oregon Health & Science University

Portland, Oregon

Parminder Raina, B.Sc., Ph.D.

McMaster University Evidence-based Practice Center

Department of Clinical Epidemiology & Biostatistics, McMaster University

Hamilton, Ontario, Canada