# Methods

## Study Overview

This project consisted of three phases, as shown in Figure 1. In phase 1 we searched the published literature for methods of stakeholder engagement to set research priorities. In phase 2 we conducted key informant (KI) interviews with individuals and organizations (i.e., researchers and policymakers) who engaged a broad range of stakeholders to identify research topics and prioritize research needs. In phase 3 we interviewed EPCs that engaged stakeholders for their future research pilot studies in 2010.

Figure 1 Study overview

Figure 1 depicts the overall study design of this Methods Report and includes three phases. Phase I, the Literature Summary, includes the literature search, selection of articles, identification of stakeholder engagement methods and a synthesis of this selected literature. Phase II, Key Informant Interviews, included recruitment of key informants, development of a semi-structured interview guide. Phase II of this report also included conducting interviews with key informants, transcription and analysis of these key informant interviews. Phase III involved the review of protocols of stakeholder engagement, development of the interview guide and conducting interviews with the Evidence-based Center (EPC) directors and staff. Interviews conducted with EPC’s were similarly transcribed and analyzed. All three phases resulted in a cumulative synthesis.

## Phase 1: Literature Summary

We searched PubMed/MEDLINE (OVID), PsychINFO (OVID), CINAHL (EBSCO), Cochrane Consumer Group, LocatorPlus(NLM online catalog), and Sociological Abstracts (CSA) from inception until August or September 2010 (see Appendix A for details). We reviewed relevant literature to identify methods and processes used to engage stakeholders in identifying and prioritizing research.

## Phase 2: Key Informant Interviews

Individuals known to have expertise engaging a broad range of stakeholders were invited to be KIs. We also asked them to recommend additional individuals and/or organizations for this project. We then reviewed the resulting list of potential KIs to ensure that it contained individuals with a breadth of experience engaging a diverse group of stakeholders (i.e., consumers, clinicians, and policymakers), and we e-mailed a description of the project and an invitation to participate to 20 KIs (Appendix B). Interviews were conducted between June 16 and July 9, 2010.

We developed a semistructured interview guide for telephone interviews with KIs (Appendix C). The guide included questions regarding experiences engaging stakeholders, the types of stakeholders engaged, the methods used to engage them, the processes used to set research priorities, and the impact of stakeholder engagement. Two investigators conducted all telephone interviews and with the permission of KIs digitally recorded and transcribed them. At the start of each interview, KIs were provided with an overview of the project and assured their identity would be kept confidential. After the interviews were completed, two investigators independently listened to the digital recordings, reviewed the transcripts to identify and code themes, and reached consensus. Four additional investigators reviewed transcripts to identify themes. All investigators met to discuss themes and resolve discrepancies.

## Disclosure and Evaluation of Conflicts of Interest

Each KI completed an EPC Conflict of Interest Disclosure Form prior to being interviewed by Oregon EPC investigators. Of the 15 KIs, 11 declared no conflicts, one provided information on financial as well as professional and business interests, and three provided information on professional and business interests. No conflicts disclosed precluded participation for any of those invited.

## Phase 3: EPC Interviews

At the conclusion of the pilots, we used semistructured interviews to evaluate the experiences of the EPC directors and project team members who engaged stakeholders to prioritize future research for the 2010 pilot projects to identify lessons learned. First, we received copies of each EPC’s protocol for the Future Research Needs project and extracted the information specific to methods for stakeholder engagement to prioritize future research to prepare for conversations. We specifically sought information on anticipated timing and approach to communication, source of stakeholders, and breadth of stakeholder engagement. We then sent letters of inquiry to all EPC directors asking them to participate in brief, semi-structured interviews to discuss their experience of engaging stakeholders in future research development (Appendix D) and developed a list of potential questions to guide the interviews (Appendix E). The discussions took place between August 19 and September 21, 2010.

At the start of the call, EPC directors and staff were provided an overview of the project and informed that their identity would be kept confidential. They were asked to describe the methods by which they had engaged stakeholders in their future research pilot projects and to consider whether they achieved appropriate balance, whether there were unforeseen challenges to managing the stakeholder process, and how they might have done it differently. The interviews were recorded and summary notes were transcribed for review. One investigator reviewed the notes and calls to identify themes and summarized them in the results below.

## Institutional Review Board

The Oregon Health & Science University and Kaiser Permanente Center for Health Research’s Institutional Review Boards determined that phases 1 and 2 did not meet the definition of human subject research per 45 CFR 46.102. The Vanderbilt University Institutional Review Board determined that their phase 3 study met the 45 CFR 46.101 (b) category (2) and approved the request for exemption.

## Peer Review

A draft of the report was sent to peer reviewers and to AHRQ. In response to the comments of the peer reviewers, revisions were made to the report and a summary of the comments and their disposition was submitted to AHRQ.