# Discussion

National attention has recently focused on engaging patients, clinicians, and policymakers to create a more patient-centered research agenda to improve health care decisionmaking in the United States.1,2 Stakeholder involvement also serves to increase researchers understanding of decisional dilemmas facing stakeholders, thus increasing the relevancy of the research and research agenda. We conducted this project to identify and recommend methods of stakeholder engagement that EPCs can apply inprioritizing future research from comparative effectiveness reviews.

Throughout the literature and in KI and EPC interviews, researchers often leveraged contacts and called upon stakeholders that they had used for other projects to identify potential new stakeholders to identify and prioritize future research. Often, researchers recruited stakeholders by e-mail. Researchers largely determined their choice of engagement method by the project’s purpose, the experience and expertise of the research team, and considerations such as budget, timeframe of the project, and type of stakeholder engaged. In general, in-person meetings, whether one-to-one or group, worked well to identify research topics or bring additional detail and meaning to priority items, whereas quantitative methods, such as voting, questionnaire, or Delphi survey, were used more frequently to produce ranked priorities. Throughout our investigation, reports in the literature and interviews with KIs and EPCs described combining quantitative and qualitative methods to engage multiple stakeholder groups to identify and prioritize research. To guide researchers’ choice of methods for stakeholder engagement and prioritization, we summarized the suitability of the engagement methods in Table 7.

Table 7 Considerations for stakeholder engagement to prioritize research

| Engagement | | | | | | | Prioritization | | | Engagement and Prioritization
| 1:1 Meetings (in-person) | 1:1 Meetings (telephone) | Focus/Working Groups | Group Virtual Meetings^a^ | Citizens’ Juries | Town-Meetings | Symposia/Conferences | Consensus (in-person) | Voting (in-person) | Nominal Group Technique | One-Time Survey | Delphi Technique
Short Timeframe | + | +++ | ++ | +++ | + | ++ | ++ | ++ | ++ | ++ | +++ | ++
Limited Budget | ++ | +++ | + | +++ | + | ++ | ++ | ++ | ++ | ++ | +++ | ++
Geographic/Transportation Barriers | + | +++ | ++ | +++ | ++ | ++ | ++ | ++ | ++ | ++ | +++ | +++
Differing Perspectives | +++ | +++ | ++ | ++ | +++ | ++ | +++ | ++ | ++ | +++ | +++ | +++
Lack of Existing Relationships | +++ | +++ | ++ | ++ | +++ | +++ | +++ | ++ | ++ | ++ | +++ | ++
Limited Stakeholder Availability | + | +++ | ++ | ++ | ++ | + | ++ | + | + | ++ | +++ | ++
Large Number of Participants | + | + | ++ | +++ | +++ | +++ | +++ | ++ | ++ | ++ | +++ | +++
Multiple Stakeholders Groups (e.g.,consumers and clinicians) | +++ | +++ | ++ | ++ | NA | +++ | +++ | ++ | ++ | +++ | +++ | +++
Stakeholders with Lack of Research Experience | +++ | +++ | +++ | ++ | +++ | +++ | +++ | ++ | ++ | ++ | ++ | +
Complex Program/Initiative | +++ | +++ | +++ | ++ | +++ | ++ | +++ | ++ | ++ | +++ | + | ++

Adapted from Preskill62

a Includes Web and conference calls.

Abbreviations: NA=not applicable.

Scale: +++ indicates that the method of engagement and/or prioritization is very useful for addressing the consideration. ++ indicates that the method is useful for addressing the consideration but other methods are better. + indicates that this method is not recommended.

Note: Methods for stakeholder engagement are described in Appendix F.

KIs and EPCs offered many suggestions for stakeholder engagement:

- Engage stakeholders early in the process
- Be attentive to building relationships and maintaining credibility and trust between the investigative team and stakeholders
- Establish credibility by consistently producing and disseminating high-quality project products
- Use multiple methods (i.e., in-person meeting and voting to obtain both details of thought and ranking of research priorities)
- Allow the time needed for engagement of all relevant stakeholder groups (for instance, consumers may require more time to recruit and engage than other groups)
- Engage stakeholders with staff who have a similar occupation or role (i.e., doctor:doctor and nurse:nurse)
- Document all stakeholder input, including audio or video recordings, that can be transcribed
- For group discussions (in person or online) employ a skilled, neutral facilitator to ensure balanced participation and focused discussions
- Plan strategies for managing disruptive or dominating stakeholders and for resolving conflicts that may arise
- If prioritizing broad or complex research topics, pare down the list in advance (i.e., through electronic vetting) or through sequential processes to ease stakeholder workload and focus attention on key topics
- Conduct icebreaker sessions at in-person activities whenever stakeholders have diverse backgrounds or are not already acquainted
- Provide brief, easy-to-understand informational materials at the beginning of engagement for complex initiatives or for stakeholders who are unfamiliar with the engagement process or the topic
- Offer opportunities for clarification of research topics (discussion or question-and-answer session). If conducting an in-person meeting, also offer these opportunities prior to the meeting.

The published literature and interviews reflected inconsistencies in terminology and a lack of clarity on concepts such as what constitutes a stakeholder, the categories and constituency of stakeholder groups, recruitment methods, and the intent and process of engagement. Establishing a common language is an important step to advancing a field. For this reason we outlined a common terminology based upon the literature (see Table 1).

Similarly, published studies often did not provide sufficient detail to evaluate the representativeness of stakeholder engagement and consideration of their input. Assurance that representative samples of stakeholders are engaged is critical to the credibility, validity, and legitimacy of the stakeholder engagement process and results. Concerns were raised by both EPCs and KIs that the stakeholders engaged were not representative of their target stakeholder populations. To our knowledge, there are not published recommendations for reporting stakeholder engagement as there are for specific types of clinical studies (e.g., CONSORT, MOOSE). We synthesized information obtained from the literature and KI and EPC interviews and created a proposed checklist to guide EPCs in the steps of stakeholder engagement and reporting (Table 8).

Table 8 Recommendations for stakeholder engagement to identify and prioritize future research

Process | Tasks | Reporting Checklist
Engagement Purpose | - State purpose of stakeholder engagement (e.g.,topic identification, prioritization, etc.) and desired results or outcomes (affects selection of recruitment, engagement, and prioritization methods) | ✓ State purpose of stakeholder engagement
Stakeholder Orientation Information and Materials | - Provide orientation to the program (e.g., Effective Health Care and Systematic Evidence Reviews); - Communicate scope, aims, and desired product/outcome of engagement; - Delineate stakeholder roles, responsibilities and expectations; - Describe extent of commitment, including methods of engagement (e.g., single Webinar on a specific date), frequency of activities, project schedule; - Explain compensation plan, if any (e.g., travel reimbursement, honorarium or other compensation); - Inform of conflict of interest disclosure requirements; - Provide contact information for project team (e.g., e-mail address and phone number of investigator and research staff contact) | ✓ Report conflicts of interest and disposition; ✓ Report any compensation
Stakeholder Recruitment | - Develop a priori list of relevant stakeholder groups, including numbers of stakeholders for each group; - Identify specific individuals within each stakeholder group to contact; - Plan one or more methods of contact (e.g., write e-mail scripts or telephone dialogue to convey expectations of stakeholders); - Plan recruitment followup (e.g., repeat e-mails or return calls for refusals or non-respondents); - Contact individual stakeholders and document results of individual responses for calculation of overall response rates; - Monitor stakeholder representativeness and distribution of stakeholder groups; add individuals to recruitment as necessary to ensure target stakeholder groups are included | ✓ State the types and proportions of stakeholders targeted by group and rationale for recruiting each group (similar to inception cohort); ✓ Report methods used to identify, sample, and contact each stakeholder group; ✓ Document recruitment dates; ✓ Report invitation and participation rates (similar to response rate); ✓ Report distribution of stakeholders planned and recruited
Methods of Engagement | - Assess and identify engagement methods and criteria for selection for each stakeholder group based on:; ○ Purpose of engagement; ○ Characteristics of stakeholders to be engaged (e.g., geographic locations, numbers of stakeholders, range of perspectives, existing relationships among stakeholders, familiarity with research area or research prioritization generally, technological capacity); ○ Context of engagement (e.g., staff, time, budget, technological capacity, complexity of research area) | ✓ Report engagement method(s) and describe process for the identification of research topics; ✓ Document number and types of engagements; ✓ Report participation rates and distribution in each engagement
Prioritization Methods | - Provide criteria for prioritization if previously established (by the sponsor or by previous engagement activity); - Document individual or group development of criteria for prioritization if not previously established | ✓ Document prioritization criteria; ✓ Describe methods of prioritization of research topics
Analysis and Synthesis | - Document, review, synthesize, and report stakeholder research priorities; ○ Overall and by stakeholder group; ○ Weighting of input if applicable (e.g., do two votes from one organization count as one or two?); - Plan for review and validation of results by stakeholders to ensure their intended priorities are accurately communicated | ✓ Provide assessment of stakeholder representativeness; ✓ Provide details of synthesis and analytic methods including weighting of stakeholder group’s responses and calculation of participation rates; ✓ Provide results both overall and by stakeholder group; ✓ Verify priorities with stakeholders
Conclusion | - Distribute final product or report to stakeholders; - Express appreciation for participation and contribution; - Gather input from stakeholders on engagement experience to evaluate the process; - Advise stakeholders of opportunities for future participation and any plans for future contact (if relationship will be maintained) | ✓ Provide prioritized list of future research topics (only after public posting/publication); ✓ Summarize lessons learned

In KI and EPC interviews, researchers differed in their views about the appropriate context for engagement of consumers. Some investigators dismissed contributions by consumers because they were felt to lack essential research experience, scientific knowledge, or technical expertise to meaningfully contribute to health care discussions or setting a research agenda. In contrast, others advocated for the inclusion of consumers and noted that they provided critical contributions to a research agenda that represented the needs of consumers and reflected health care issues commonly faced by their communities. They felt that consumers meaningfully contributed to all phases of their research process including identification and prioritization of research topics, study design, analyses, drafting of manuscripts, and presenting research results.

Specifically regarding EPCs, many were interested in having assistance with the engagement process, including identifying who to engage, to what extent to engage each stakeholder group, how to measure the representativeness of each stakeholder, and the optimal balance of stakeholders that should be used to identify and prioritize future research needs. Some EPCs reported a lack of qualitative expertise. Others reported challenges in engaging certain stakeholders such as Federal stakeholders. They would appreciate the help of AHRQ in encouraging Federal participation in future research needs projects.

When scanning literature and interviewing KIs and EPCs, investigators often did not consider how to weigh input obtained from each stakeholder group. Engagement of multiple stakeholders groups is very common and was reported in a majority of the studies that were reviewed and the interviews that were conducted with KIs and EPCs. Should input be weighted equally for each group? The issue of weighting should be considered during recruitment because it will affect the composition of stakeholder recruitment lists, and it should also be considered when synthesizing and analyzing stakeholder input. For example, if a researcher wanted to elicit both consumer and clinician input but valued consumer input more, the researcher could engage 20 consumers and 10 clinicians and prioritize research by one vote per person. This would unequally weight the prioritization process in favor of consumers. In the analytic phase, the same researcher could weigh the votes differently if she wanted them to have equal input. For example, consumers’ votes could be weighted by 0.5 rather than 1. There are several ways that this can be accomplished. Careful thought should be given to both the selection and analytic strategies when engaging multiple groups. In addition, the strategies should be explicit.