# Conclusions

To identify methods of stakeholder engagement to set research priorities, we conducted a literature scan, interviewed KIs with experience in engaging stakeholders to prioritize research, and interviewed EPCs about their recent projects to engage stakeholders in identifying and prioritizing future research needs for a previously completed comparative effectiveness review. As part of this process, we identified the following considerations:

1. Use of consistent terminology and definitions is important throughout the stakeholder engagement process, from planning to implementation to evaluation.
2. The intent of stakeholder engagement is important in determining the methods of engagement. In-person methods are helpful for brainstorming, identifying topics, clarifying issues, and eliciting a deeper understanding, while quantitative methods such as voting and Delphi are best applied to prioritize research. A flexible approach using mixed methods may be required to engage multiple stakeholder groups.
3. Engaging stakeholders early and maintaining relationships are important to building trust and credibility. Nearly all KIs emphasized that the key to establishing credibility and engaging stakeholders for future research prioritization is to establish ongoing, long-term relationships with stakeholders. Further feedback for fostering stakeholder relationships included finding a common ground, partnership, understanding needs, respect, trust, and commitment.
4. Assurance that representative samples of stakeholders are engaged is critical to the credibility and legitimacy of the stakeholder engagement process and results.
5. When multiple stakeholder groups are engaged, special consideration should be given to how to weight input from each group. The issue of weighting should be addressed at the outset during recruitment because it will affect the composition of stakeholder recruitment lists, and it should also be considered when synthesizing and analyzing stakeholder input.

This research project is one of the first efforts to identify and recommend methods for EPC stakeholder engagement for future research identification and prioritization. KI interviews provided critical, practical information from researchers with extensive experience engaging a broad range of stakeholders. The KIs interviewed were a select group of researchers, most of whom were known by the EPC staff, and while leveraging contacts helped to ensure participation from KIs within a short timeframe, their experiences reflected only a small part of the stakeholder engagement experience. Despite this limitation, our synthesis of information from the literature scan and the interviews with EPCs and KIs generally agreed on basic themes. Our understanding of the stakeholder engagement process for research identification and prioritization is evolving, and we expect that the stakeholder engagement and prioritization recommendations will continue to be refined as we expand methodology for future research needs documentation as part of the comparative effectiveness review process.