# Background

National attention has recently focused on engaging stakeholders to create a more patient-centered research agenda to improve health care decisionmaking in the United States.1,2 Specifically, patients and physicians seek to apply current research to their treatment decisions, and they require high-quality evidence that directly addresses their information needs.3 In response to this need, there is growing interest among the research community to engage the public in the research development process. Consumer involvement has been shown to positively impact research and its applicability to the public,4 and the Agency for Healthcare Research and Quality (AHRQ) has emphasized the importance of considering the patient perspective during all aspects of comprehensive comparative effectiveness reviews (CERs).

Engaging stakeholders to identify and prioritize future research for CERs is a new process, and the methods to delineate future research needs are not well developed. Evidence-based Practice Centers (EPCs) have engaged individuals and organizations outside of the EPC program in their reviews, especially in the early phases for input on topic development and topic refinement.5 Recently, some EPCs have initiated new activities engaging stakeholders to identify and prioritize future research needs following completion of CERs.

To develop guidance for a systematic approach to identifying future research needs for the EPCs, AHRQ requested that the Oregon and Vanderbilt EPCs conduct this project to better understand the various methods for engaging stakeholders in defining and prioritizing research needs. In response to this request, the Oregon and Vanderbilt EPCs conducted a methods project to identify and describe methods used in engaging stakeholders to prioritize research needs, evaluate the tradeoffs of different engagement methods, describe methods for analyzing stakeholder input, and describe the experiences of EPCs who engaged stakeholders for their future research needs pilot studies. This is one of a series of methods projects to inform and systematize AHRQ’s guidance related to identification and prioritization of future research needs.