# Appendix H Literature Results: Stakeholder Participation Rates by Engagement Method

Method of Engagement | Purpose | Participants | Stakeholder Group(s) | A priori Identification | Invited (N) | Accepted/Replied (n_a_) | Declined (n_d_) | Participated (n_p_) | Participation Rate (n_p_)/N
1:1 Interviews and Focus Groups | To identify research priorities in nursing and midwifery services1 | 1. Service users; 2. Researchers, policymakers, health professionals | Consumers Researchers Clinicians Policy-makers | Yes | 1. 126; 2. 100 | | | 1. 32; 2. 64 | 1. 25%; 2. 64%
Focus Groups | To determine patients’ priorities in health care2 | Patients | Consumers | Yes | 25 | 24 | 1 | 19 | 76%
Consensus Forum | To collect and report seating and wheeled mobility research priorities3 | Clinicians Policymakers Manufacturers Federal research funders Researchers | Clinicians Policy-makers Manufacturers Research funders Researchers | Yes | 110 | 90 | NR | 67 | 61%
Workshop | To engage consumers to understand barriers in participation in developing public health research agendas4 | 20 consumers/organizations Community service organizations (7), consumer health groups (5), unions (3), employer organizations (3), local government (1) agency and self- employed individuals(2) | Consumers | Yes | 20 organizations and individuals | 15 | 5 (no response or not interested) | 0 | 0%
Questionnaire | Open-ended and structured questions to compare and clinician preferences for research on homeless veterans5 | 1. Veterans; 2. Health Professionals working for VA | Consumers Clinicians | Yes | Unclear | | NR | 1. 87; 2. 28 | 1. 61% of eligible veterans; 2. 82% of health professionals working on those three days
Questionnaire | Web-based questionnaire to prioritize research needs in infections disease research6 | Clinicians, decisionmakers and researchers | Clinicians Policy-makers Researchers | Yes | 563 sent questionnaire | 185 (returned questionnaire) | NR | 147 (complete questionnaire received) | 147/563= 26%
Questionnaire | To examine the current distribution of mental health research in Australia and to compare with priorities of various stakeholder groups7 | A. Random sample of researchers, general practitioners, psychiatrists, clinical psychologists, and mental health nurses; B. Funders (grant panel from National Mental Health Review Panel); C. Research Committee Members of research funder (ARHRF); D. NMHWG; E. Consumer/Caregiver Advocacy Organizations; F. Consumers and caregivers by snowball sampling | Consumers Clinicians Researchers Research funders | Yes | A. 200 per group; B. 11; C. 10; D. 9; E. 83; F. 179 | | | A. 100, 58, 105, 106, 120; B. 11; C. 10; D. 9; E. 83; F. 179 | Reported as number responded/(number samples-number not contactable); A. 100 (56%), 58 (30%), 105 (53%), 106 (53%), 120 (60%); B. 10 (91%); C. 8 (80%); D. 6 (67%); E. 59 (72%); F. 114 (64%)
Questionnaire | Questionnaire developed with WHO to determine mental health research priorities in low and middle- income countries8 | 1. Researchers; 2. Decisionmakers, university administrators and consumers | Researchers Policy-makers Consumers | Yes | 1. 4633; 2. 3829, sent questionnaire | | | | 1. 21.1%; 2. 10.1%
Questionnaire | To determine research priorities in patients with COPD9 | Patients | Consumers | Yes | 1. 1042 | | | 1. 244 | 1. 23.4%
Delphi Technique | To identify and compare research priorities within mental health care by different stakeholder groups10 | 1. Consumers; 2. Cares; 3. Health Professionals; 4. Service Managers | Consumers Clinicians | Yes | 1. 34; 2. 26; 3. 35; 4. 23 | | | | Round 1; 1. 29 (85%); 2. 26 (100%); 3. 31 (89%); 4. 23 (100%); Round 2:; 1. 27 (79%); 2. 26 (100%); 3. 34 (97%); 4. 21 (91%); Round 3:; 1. 25 (74%); 2. 26 (100%); 3. 33 (94%); 4. 22 (96%)
Delphi Technique | To reach consensus on research priorities for cerebral palsy11 | 1. Consumers; 2. Researchers/clinicians | Consumers Researchers Clinicians | Yes | 1. 50; 2. 180; 3. 80 | | | | Round 1; 1. 20 (38%); 2. 76 (42%); 3. 31 (39%); Round 2; 1. 20 (38%); 2. 45 (25%); 3. 19 (24%); Round 3; 1. 19 (38%); 2. 32 (18%); 3. 18 (23%)
Delphi Technique | To prioritize low back research12 | Health Professionals | Clinicians | Yes | 86 | | | 70 | Round 1=70 (81%) Round 2=52 (60%) Round 3=50 (58%)
Delphi Technique | To identify research priorities in hospice care for children13 | Consumers, health professionals and policymakers | Consumers Clinicians Policy-makers | Yes | 621 | | | 274 | Round 1 (N/A: Focus groups) Round 2= 274 (44%) Round 3=204 (33%)
Delphi Technique | To identify research priorities for midwifery in Ireland14 | Clinicians (midwives) | Clinicians | Yes | 334 | | | 142 | Round 1=142 (43%) Round 2=121 (36%) Round 3=98 (29%)
Delphi Technique | To identify top research priorities in health care15 | Policymakers, health professionals and consumer advocates | Policy-makers Clinicians Consumers | Yes | 293 | | | | Round 1 = NR Round 2=165 (56%)

Abbreviations: ARHRF=Australian Rotary Health Research Fund; COPD=chronic obstructive pulmonary disease; NMHWG=National Mental Health Working Group; NR=not reported; VA=Veterans Affairs; WHO=World Health Organization

## References: Appendix H

1 Ross F, Smith E, Mackenzie A, et al. (2004). Identifying research priorities in nursing and midwifery service delivery and organisation: a scoping study. International Journal of Nursing Studies.
2 Perkins P, Barclay S, Booth S. (2007). What are patients’ priorities for palliative care research? Focus group study. Palliat Med.
3 Sprigle S, Cohen L, Davis K. (2007). Establishing seating and wheeled mobility research priorities. Disability & Rehabilitation: Assistive Technology.
4 Graham J, Broom D, Whittaker A. (2001). Consulting about consulting: challenges to effective consulting about public health research. Health Expect.
5 Cohen CI, D’Onofrio A, Larkin L, et al. (1999). A comparison of consumer and provider preferences for research on homeless veterans. Community Mental Health Journal.
6 Patrick DM, Remple VP, Kendall P, et al. (2006). Needs, gaps and opportunities for infectious disease research in British Columbia: a perspective from population and public health. Can J Public Health.
7 Griffiths KM, Jorm AF, Christensen H, et al. (2002). Research priorities in mental health, Part 2: an evaluationof the current research effort against stakeholders’ priorities. Aust N Z J Psychiatry.
8 Sharan P, Gallo C, Gureje O, et al. (2009). Mental health research priorities in low- and middle-income countries of Africa, Asia, Latin America and the Caribbean. Br J Psychiatry.
9 Caron-Flinterman JF, Broerse JE, Teerling J, et al. (2005). Patients’ priorities concerning health research: the case of asthma and COPD research in the Netherlands. Health Expect.
10 Owens C, Ley A, Aitken P. (2008). Do different stakeholder groups share mental health research priorities? A four-arm Delphi study. Health Expect.
11 McIntyre S, Novak I, Cusick A. (2010). Consensus research priorities for cerebral palsy: a Delphi survey of consumers, researchers, and clinicians. Dev Med Child Neurol.
12 Henschke N, Maher CG, Refshauge KM, et al. (2007). Low back pain research priorities: a survey of primary care practitioners. BMC Fam Pract.
13 Malcolm C, Knighting K, Forbat L, et al. (2009). Prioritization of future research topics for children’s hospice care by its key stakeholders: a Delphi study. Palliat Med.
14 Butler MM, Meehan TC, Kemple M, et al. (2009). Identifying research priorities for midwifery in Ireland. Midwifery.
15 Schopper D, Torres AM, Pereira J, et al. (2000). Setting health priorities in a Swiss canton: what do different methods tell us?. J Epidemiol Community Health.