# Appendix G Strengths and Limitations of Stakeholder Engagement Methods

Method | Strengths | Limitations
Delphi 1 | - Consensus-building nature of Delphi technique combines rigor of traditional surveys and the collaborative effect of focus groups.; - Anonymity eliminates potential sources of conflict and enables participants to express views freely.; - Multiple rounds provide opportunities for revising individual views in response to group trends. Particularly effective when:; 1. Consensus is sought in an area where none previously existed;; 2. Research problem does not lend itself to precise analytical approaches but can be illuminated by subjective collective judgments;; 3. Study participants have diverse backgrounds in their expertise and consensus cannot easily be reached;; 4. More research participants are needed than can effectively interact face-to-face; and; 5. Frequent meetings of all participants are not feasible. | - Large time commitment precludes some participants from participating in every round.; - Anonymity may lower the incentive for accountability and negatively impact response rates.; - Potential for manipulation of consensus; multiple rounds may limit ability to remain impartial in light of others views and social desirability bias may influence participants’ responses.
Focus Groups 2–8 | - Participants are able to draw upon their own experiences to stimulate and guide discussion. Flexible nature of questioning allows exploration of wide range of opinions, attitudes and perceptions.; - Ability to focus discussions on issues specific to each group and how research could address them.; - Particularly useful when dealing with sensitive subjects; - More efficient use of time and resources than one-on-one interviews.; - Effective method for engaging consumers. | - Time consuming, difficult to coordinate and carry out.; - Some individuals may be reticent to express their opinions in a group context.; - Group dynamics may hamper prioritization process.; - Framing of issues by the interviewer may influence the prioritization process.; - Small sample size limits generalizability of findings.; - May produce divergent views and can be difficult to reach consensus.
In-Person Interviews9,10 | - Effective method for capturing community and individual perspectives.; - Low cost if limited geographic dispersion.; - Good way to facilitate collaboration and identify priorities with decisionmaker buy-in. | - Sample size usually too small to support statistical analysis of differences in perspectives; results not generalizable.; - Time consuming if want to engage many stakeholders.; - Difficult when stakeholders are geographically dispersed.; - Inability to establish consensus among stakeholders.
Questionnaires7,11,12 | - Ability to include individuals from a range of socioeconomic and professional backgrounds and with varying levels of experience with the topic.; - Easy to complete and can be provided in a wide variety of formats.; - Stakeholders do not need to be present and can complete the questionnaire when it is convenient for them.; - Anonymity enables stakeholders to share their views without concern for the reactions of others.; - Ability to query a large sample of stakeholders. | - Low response rate. Anonymity can lead to low levels of accountability.; - Inability to clarify responses or to further probe as to meaning behind different opinions and perspectives.; - Inability to establish consensus among stakeholders.
Symposiums/Conferences13,14 | - Ability to identify overarching themes.; - Can be used to check validity of research priorities generated by key informant interviews and focus groups. | - Difficult to plan and coordinate.; - Expensive.; - Sample may not be representative.; - Some participants may not feel comfortable expressing their opinions in a formal group context; - Prioritization process may be dominated by a vocal minority.
Citizen’s Jury12,15–17 | - Useful method for actively engaging and eliciting views from the public.; - Provides an opportunity to bring together diverse set of citizens.; - Bridges the gap between “top down” and “bottom up” involvement.; - Program flexibility allows discussion to reach natural conclusion.; - All jurors have an equal opportunity to participate in the process and express their views and even minority views are included in final outcome.; - Includes an education component not typically included in other methods.; - Allows space for findings to contain disagreement and uncertainty. | - Overall influence of jury on research activity difficult to assess.; - Costly and time-consuming process.; - Findings not always generalizable to the larger population.; - Can be challenging to educate general public on the topic to be discussed in such a short time frame.; - Jurors often struggle to separate research from service provision.; - Strong personalities can sway jurors and inhibit discussion.
Nominal Group Technique 18 | - Particularly good for a collaborative, community based project.; - Enables all workshop participants to have an equal voice.; - Ensures that ideas of members are shared and commented on in a non-threatening environment. | - Difficult to prioritize future research needs.; - Costly and time-consuming.; - Samples often not representative and findings not generalizable to larger population.
Scoping Study (Literature Review With Key Informant Interviews and Focus Groups) 13 | - Incorporates two methodological approaches: (1) a search and analysis of existing literature and (2) expert opinions and perspectives from stakeholders in the field. | - Lack of methodological quality review can lead to uncertainty regarding how to weigh grey literature when identifying strengths and shortcomings of the evidence.; - Does not incorporate non-expert opinions and priorities.

## References: Appendix G

1 McIntyre S, Novak I, Cusick A. (2010). Consensus research priorities for cerebral palsy: a Delphi survey of consumers, researchers, and clinicians. Dev Med Child Neurol.
2 Wright D, Corner J, Hopkinson J, et al. (2006). Listening to the views of people affected by cancer about cancer research: an example of participatory research in setting the cancer research agenda. Health Expect.
3 Robotin MC, Jones SC, Biankin AV, et al. (2010). Defining research priorities for pancreatic cancer in Australia: results of a consensus development process. Cancer Causes and Control.
4 Perkins P, Barclay S, Booth S. (2007). What are patients’ priorities for palliative care research? Focus group study. Palliat Med.
5 Ross F, Smith E, Mackenzie A, et al. (2004). Identifying research priorities in nursing and midwifery service delivery and organisation: a scoping study. International Journal of Nursing Studies.
6 Brown K, Dyas J, Chahal P, et al. (2006). Discovering the research priorities of people with diabetes in a multicultural community: a focus group study. Br J Gen Pract.
7 Caron-Flinterman JF, Broerse JE, Teerling J, et al. (2005). Patients’ priorities concerning health research: the case of asthma and COPD research in the Netherlands. Health Expect.
8 Niner S, Pirkis J, Krysinska K, et al. (2009). Research priorities in suicide prevention: a qualitative study of stakeholders’ views. Australian e-Journal for the Advancement of Mental Health.
9 Crowe JL, Keifer MC, Salazar MK. (2008). Striving to provide opportunities for farm worker community participation in research. J Agric Saf Health.
10 Schur CL, Berk ML, Silver LE, et al. (2009). Connecting the ivory tower to Main Street: setting research priorities for real-world impact. Health Aff 2009.
11 Perkins P, Booth S, Vowler SL, et al. (2008). What are patients’ priorities for palliative care research?—a questionnaire study. Palliative Medicine.
12 Entwistle V, Calnan M, Dieppe P. (2008). Consumer involvement in setting the health services research agenda: persistent questions of value. J Health Serv Res Policy.
13 O’Brien K, Wilkins A, Zack E, et al. (2010). Scoping the field: identifying key research priorities in HIV and rehabilitation. AIDS Behav.
14 Rose D, Fleischman P, Wykes T. (2008). What are mental health service users’ priorities for research in the UK?. Journal of Mental Health.
15 Herbison P, Hay-Smith J, Paterson H, et al. (2009). Research priorities in urinary incontinence: results from citizens’ juries. BJOG.
16 Menon D, Stafinski T. (2008). Engaging the public in priority-setting for health technology assessment: findings from a citizens’ jury. Health Expect.
17 Gooberman-Hill R, Horwood J, Calnan M. (2008). Citizens’ juries in planning research priorities: process, engagement and outcome. Health Expect.
18 Baker PG, Hegney D, Rogers-Clark C, et al. (2004). Planning research in rural and remote areas. Rural Remote Health.