# Appendix E Interview Guide for EPC Interviews

For continuous quality improvement, we are collecting EPC director feedback on the recent engagement process with/for __________________ (identify project). We will be having a conversation to that I can better understand your perspective on the process of engaging stakeholders in decisionmaking and how satisfied you are with the outcome of the project. Please be open and honest in your responses. This interview will be audio-recorded. Audio tapes will not be released. We will not quote you.

1. Were you able to identify and bring together the right balance of stakeholders? Were there any significant stakeholders you would have liked to have included in the process but could not access?
2. Do you think the stakeholders understood why they were invited to engage? Did they understand the issues you wanted them to engage on?
3. At the start of the project, were there any conflicts of interest?
4. How did you communicate the scope, aims and objectives to all stakeholders? Did the scope, aims and objectives change over the course of the project timeline?
5. Did you elicit input on the engagement strategy? Was it helpful?
6. Did you establish clear ground rules? Did all members adhere to the ground rules?
7. When members failed to adhere to the ground rules, did you feel equipped to handle the breech?
8. Did other stakeholders handle the breech? Which approach was successful?
9. In retrospect, do you feel that there were ground rules that were not established but needed?
10. Did any stakeholders dominate the conversation? Were any disruptive?
11. How comfortable were you managing the relationship between stakeholders?
12. How well did you manage our relationship with each stakeholder?
13. Did you notice that stakeholder fatigue set in? (If no, skip to Q13.) How did you manage it?
14. Did you notice any conflict between stakeholders? (If no, skip to Q14.) How did you manage conflict between stakeholders?
15. Was there a formal mechanism for stakeholders to reviewing decisions and addressing disagreement constructively?
16. How did you coordinate communication to stakeholders? How effective was that?
17. How did you communicate the process to stakeholders?
18. How satisfied were you with the level of stakeholder involvement in the decision-making process?
19. What was the value of the engagement? Did it really lead to better decisionmaking? Did it legitimize the decisionmaking process and outcome? Did it build trust -- between research institutions, professional organizations, and AHRQ? Was it worth taking the time to involve stakeholders in this manner or would you suggest taking a different approach next time?
20. Overall, how satisfied were you with the process.
21. Overall, how satisfied were you with the outcome.

Thank you for your time and thoughtful answers.