# Appendix D Invitation Letter to Evidence-based Practice Centers

Good morning.

Thank you very much for sending us your Future Research Pilot Protocol as part of our methods project on engaging stakeholders. It is time for the next step in our project; namely, for us to conduct interviews with appropriate EPC team members/staff. We hope to conduct these interviews during the month of August. Our goal will be to understand:

1. The degree to which your intended approach to engaging stakeholders succeeded;
2. Specific elements of your approach that you felt facilitated engaging stakeholders; and
3. Challenges that you encountered in the process

We will collate all of the information into “lessons learned” and combine this information with similar data being gathered from groups outside of the EPC program, with a track record in engaging stakeholders for setting research agendas.

Ideally, we will also speak with stakeholders about their experiences, so please consider whether you would be willing to identify 2–3 individuals from your project with whom you recommend we speak.

Involvement includes participation in the following:

- Listing any knowledge gaps you feel are related to stakeholder engagement or the EPC future research project by online submission of information or individual phone conversations (up to 1 hour)

Participation in this project is completely voluntary, and you may discontinue your participation at any time.

## Confidentiality

All the information we receive from you, including your name and any other identifying information (if applicable), will be strictly confidential and will be on password protected server maintained by computer services at Vanderbilt University. We will not identify you or use any information that would make it possible for anyone to identify you in any presentation or written report about this project. Individual and group conference calls will be recorded so that a comprehensive transcript can be produced. Digital files of the recordings will be destroyed upon completion of the transcript approximately 7–10 days after the call and names and other identifying information will be deleted from all electronic and paper copies of transcripts.

Since names are not required as part of the study data, no identifying information such as the participants’ names will be part of the study data. If this information is recorded on phone conversations or documents we receive from you it will be kept only to determine that we have received all responses and will be destroyed or deleted within 7 days of the submission of the final report on or about September 30, 2010.

## Risks and Benefits of Participating

There is a slight risk your organization’s name could be disclosed, but all efforts are made to reduce this possibility. The benefit of participating in this project is the knowledge that you are assisting AHRQ and the Vanderbilt Evidence-based Practice Center in moving the research related to engaging stakeholders forward. Responses from each participant will be combined with those from representatives of other organizations and a summary of this information will be generated by analysts at the Vanderbilt EPC. No individual names will be mentioned in the summary.

If you have questions about the rights of participants in a research project, you may contact the Vanderbilt Institutional Review Board directly at 1-866-224-8273 or www.mc.vanderbilt.edu/irb.

If you have any questions regarding this project, you may “reply” to this email and we will respond to your questions as soon as possible. You may also call us at (615) 936-5357.

Please let us know the right person, at your EPC, to request this interview by contacting Kathy Lee by email at kathy.e.lee@vanderbilt.edu or by phone at (615) 936-5357. We would very much appreciate hearing from you by August 19, 2010. Once we have the correct contact, we will be in touch to schedule the interview.

Thank you,

Kathy Lee for

Melissa McPheeters, PhD, MPH

Co-director, Vanderbilt Evidence-based Practice Center

Deputy Director, Women’s Health Research

Institute for Medicine and Public Health

Vanderbilt University Medical Center

2525 West End Avenue, Suite 600, 6^th^ Floor

Nashville, TN 37203-1738

(Tel.) 615.936.8317

(Fax) 615.936.8291

(Cell) 615.574.4700

melissa.mcpheeters@vanderbilt.edu