# Appendix C Key Informant Interview Guide

Respondent Name
Title
Phone
Interviewers
Date Completed
COI Received
Interview File

## I Introduction

- Introduce yourself:
  Good afternoon, is this (name of KI)?
  Interviewer 1: Hello, This is (name of interviewer 1). I am an investigator with the Oregon Evidence-based Practice Center (aka EPC). Thank you for joining us today. (Name of interviewer 2) is also here with me and I will let (interviewer 2) her introduce herself.
  Interviewer 2: Introduces self.
- Explain project:
  Interviewer 1: As mentioned in our e-mail,
  The Oregon Evidence-based Practice Center, along with the Vanderbilt University EPC, is conducting a project to better understand methods that have been used to engage stakeholders (such as policymakers, clinicians, researchers, and consumers) to identify and prioritize research needs. Currently, the EPCs use a variety of methods to engage stakeholders throughout the systematic review process and use their input to set priorities for future research.
  Our goal is to identify a process that they could be used by ALL EPCs at the conclusion of each systematic review to identify and prioritize research gaps related to a given topic.
  To achieve this goal, we are conducting interviews with individuals who have engaged stakeholders. We want to explore the [underlined: strengths and challenges of engaging various types of stakeholders and identify the methods that are most effective for working with different stakeholder groups]. We are particularly interested in hearing about your experience in this area through your work with (insert individual’s company/organization information below):
  Interviewer 1: Before we start, we want to let you know that we will be recording this interview and it will be transcribed to ensure that all of the information that we document is accurate. Results from interviews will not specifically identify individuals interviewed or their organizations. Rather, the results will be reported in aggregate and by the types of stakeholders that have been engaged. Do you have any questions? Is it ok to begin the interview?

## II Possible Key Informant Interview Questions

### Engaging Stakeholders

1. Can you describe your experience in engaging stakeholders?
  Note: For each research purpose or stakeholder group, repeat questions a-b.
  a. What are general groups of stakeholders that you have engaged?
    i. How did you select these stakeholder groups?
      1. If provide detailed list ask why did you select these types of stakeholders?
        a. Purpose: Want to know [underlined: how] selected and [underlined: purpose] of engagement?
    ii. How did you approach them? What was most effective? Least effective?
      1. Did you initially try other methods of engagement?
    iii. Were there methods of stakeholder engagement that facilitated their participation? What were they?
    iv. Were there barriers to engaging important stakeholder groups?
      1. If so, what were they?
    v. Do you feel that all relevant stakeholder groups were able to be engaged?
      1. IF NO, what additional stakeholder group(s) would you like to have included?
  b. In general, what were your response rates?
2. What strategies did you use to bring stakeholders together or to elicit feedback from them?
  (Prompt: Have you ever used…individual calls, group calls, Web-based applications, in-person meetings?)
  a. Were the methods that you used the same or different for different types of stakeholders that you engaged? If so, how did that work?
  b. You mentioned you’ve used ------ (method).
    Note: Repeat questions for each method
    i. Why did you choose this method?
    ii. What do you think is the right time to engage stakeholders?
    iii. Did you do anything to keep them engaged?
    iv. Was it successful?
    v. What were the strengths of using this method?
    vi. What were the limitations or challenges associated with using this method?
    vii. When you used this method, was this the first strategy that you used to engage stakeholder?
    viii. IF NO, what was the first method that you used?
      a. Why change?
    ix. IF A METHOD WAS USED THAT ENGAGED MULTIPLE GROUPS SIMULTANEOUSLY (e.g. focus groups), did you feel that the responses were balanced or were they weighted by the input of a few individuals?
      - How did this impact your research?
      - IF NOT BALANCED: Are there strategies that you think could help to create more balanced input in future stakeholder engagements?
      - IF BALANCED: What strategies did you use to create balanced input?
  c. How was information organized in order to facilitate stakeholder input? Were there any documents or presentations given to stakeholders to provide background information to facilitate these processes? Was this successful? Were other formats considered?
3. What impact did involving stakeholders have on making decisions or setting priorities?
4. In the process you just described, what do you think were the critical elements that helped you be successful in gathering stakeholder input?
5. If you were recommending one or more methods to use to engage stakeholders in setting research questions and priorities, which method or methods would you recommend?
  Note: May want to ask also about methods to obtain balanced input
6. In thinking about the types of information you’ve gathered from stakeholders, what has been the best strategy for synthesizing and/or analyzing their input?
  (Prompt: How have you gone about analyzing data for stakeholder input?)
  a. For each method
    i. Why did you choose this method?
    ii. How long did it take to synthesize and analyze/assess their input?
    iii. Was it resource intensive (trying to get at whether or not it was worth the effort)?
7. How has stakeholder engagement impacted future projects?
8. How do you measure success of stakeholder engagement?

### Setting Priorities

We are also interested in understanding how criteria are defined for prioritizing research gaps and how research needs are prioritized.

1. Have you been involved with setting research priorities?
  a. In your opinion, what approach(es) have been the most successful for research prioritization? Why?
    i. Does this differ by stakeholder?
    ii. Does this differ by project purpose?
  b. Did you provide stakeholders with specific criteria to prioritize?
  c. What criteria did you provide for stakeholders to prioritize? (If they mention specific criteria, ask if they could e-mail any written criteria that they have used)
    i. Did you use the same criteria for different groups of stakeholders? IF YES, for each stakeholder group which criteria did you use and why did you choose it?
    ii. Did you use the same criteria for different research questions? IF YES, which criteria did you use for each research questions?
2. How has stakeholder prioritization impacted future projects?
3. How do you measure success of stakeholder prioritization?

## III Conclusions

- Interviewer 1: Thank you very much for your time and for sharing your experiences with us.
  Do you have any additional comments or insight about the processes of stakeholder engagement and research prioritization?
  Do you have any questions for us?
  Again thank you very much.
  Have a good day.