# Appendix B Key Informant Interview Invitation and Conflict of Interest Request

Dear <<insert Key Informant name>>,

[underlined: <<Insert name of interviewer>>] previously contacted you about interviews for the EPC Future Research Methods Project. The Oregon EPC, along with the Vanderbilt University EPC, is conducting a project to better understand the various methods that have been used to engage stakeholders in identifying and prioritizing research needs. The ultimate goal is to identify a process that all EPCs could use at the conclusion of each systematic review to identify and prioritize research gaps related to a given topic.

We are scheduling telephone interviews with individuals who have engaged stakeholders (e.g., patients, clinicians, policy makers, researchers, etc.) in the past to explore the strengths and challenges of engaging various stakeholders and to identify the methods that are most effective for working with different stakeholder groups. We would like to know more about your experience in this area through your work with <<insert relevant work here>>. Would you be available for a telephone interview on <<insert date>>between<< insert time>>? We anticipate that the interview will take no longer than one hour.

We appreciate your participation in this important research and look forward to speaking with you. AHRQ requires that we provide COI documentation for each person who is interviewed. As such, we ask that you please complete the Conflict of Interest form (COI) (attached) and return it to us by <<insert date>>. To return it to us, please use one of the following options:

[underlined: By email]: Scan the COI and email to<< insert email>>

[underlined: By fax]: <<insert fax number>>

Attention: <<insert name>>

[underlined: By mail]:

<<insert address>>

Please do not hesitate to contact us if you have any questions regarding this project and your participation.

Thank you,

Oregon Evidence-based Practice Center

Oregon Health and Science University

3181 SW Sam Jackson Park Road

Mail code: BICC

Portland, Oregon 97239-3098