# Appendix A Engaging Stakeholders: Literature Review Search Strategies

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1947 to September Week 1 2010>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 21, 2010>
Date Searched: 9/22/2010
Search Strategy:
1 | *Health Services Research/ (10736)
2 | exp *Community-Based Participatory Research/ (270)
3 | exp *Comparative Effectiveness Research/ (139)
4 | exp *Biomedical Research/ (22652)
5 | exp *Translational Research/ (276)
6 | *Research/ (116380)
7 | 1 or 2 or 3 or 4 or 5 or 6 (147771)
8 | *Consumer Participation/ (6637)
9 | exp *Patient Participation/ (7180)
10 | "stakeholder*".ab,ti. (7173)
11 | 8 or 9 or 10 (20669)
12 | "priorit*".ab,ti. (42997)
13 | 7 and 11 and 12 (127)
14 | "consumer*".ab,ti. (29730)
15 | "stakeholder*".ab,ti. (7173)
16 | "citizen*".ab,ti. (9151)
17 | "policy maker".af. (99)
18 | "policy makers".af. (6717)
19 | "policymaker*".af. (3418)
20 | 14 or 15 or 16 or 17 or 18 or 19 (54221)
21 | research.ab,ti. (587579)
22 | "priorit*".ab,ti. (42997)
23 | 21 and 22 (9960)
24 | 20 and 23 (843)
25 | "research agenda".ab,ti. (2132)
26 | "research agendas".ab,ti. (230)
27 | 25 or 26 (2335)
28 | setting.af. (263446)
29 | 27 and 28 (208)
30 | 13 or 24 or 29 (1063)
31 | limit 30 to english language (1030)

Database: PsycINFO <1806 to September Week 3 2010>
Date Searched: 9/22/2010
Search Strategy:
1 | health services research.mp. (565)
2 | community-based participatory research.mp. (307)
3 | comparative effectiveness research.mp. (36)
4 | biomedical research.mp. (581)
5 | translational research.mp. (393)
6 | *research/ (29991)
7 | 1 or 2 or 3 or 4 or 5 or 6 (31440)
8 | consumer participation.mp. (152)
9 | exp *Patient Participation/ (791)
10 | "stakeholder*".ab,ti. (5999)
11 | 8 or 9 or 10 (6904)
12 | "priorit*".ab,ti. (14412)
13 | 7 and 10 and 12 (36)
14 | consumer*.ab,ti. (24345)
15 | "stakeholder*".ab,ti. (5999)
16 | "citizen*".ab,ti. (12093)
17 | "policy maker".af. (134)
18 | "policy makers".af. (6998)
19 | "policymaker*".af. (4594)
20 | 14 or 15 or 16 or 17 or 18 or 19 (51976)
21 | research.ab,ti. (467262)
22 | "priorit*".ab,ti. (14412)
23 | 21 and 22 (4782)
24 | 20 and 23 (484)
25 | "research agenda".ab,ti. (2312)
26 | "research agendas".ab,ti. (352)
27 | 25 or 26 (2641)
28 | setting.af. (124314)
29 | 27 and 28 (304)
30 | 13 or 24 or 29 (778)
31 | limit 30 to english language (767)

Date Searched: 8/20/10
CINAHL (EBSCO)
# | Query | Results
S31 | S24 or S29 Limiters - English Language | 333
S30 | S24 or S29 | 338
S29 | S27 and S28 | 114
S28 | setting | 70777
S27 | S25 or S26 | 1094
S26 | "research agendas" | 95
S25 | "research agenda" | 1013
S24 | S20 and S23 | 228
S23 | S21 and S22 | 2408
S22 | priorit# | 6990
S21 | research | 328696
S20 | S14 or S15 or S16 or S17 or S18 or S19 | 44593
S19 | policymaker# | 1180
S18 | "policy makers" | 2678
S17 | "policy maker" | 32
S16 | citizen# | 2481
S15 | stakeholder# | 3468
S14 | consumer* | 36039
S13 | S7 and S11 and S12 | 10
S12 | priorit# | 6990
S11 | S8 or S9 or S10 | 8269
S10 | stakeholder# | 3468
S9 | patient participation | 467
S8 | (MM "Consumer Participation") | 4580
S7 | S1 or S2 or S3 or S4 or S5 or S6 | 10125
S6 | (MM "Research") | 7352
S5 | translational research | 400
S4 | biomedical research | 463
S3 | comparative effectiveness research | 177
S2 | community-based participatory research | 308
S1 | (MM "Health Services Research") | 1608
[after deduplication 168 unique references]

Search Date: 8/25/10
Database: Sociological Abstracts (CSA)
Search Strategy:
((KW=(consumer* or stakeholder* or citizen*) or KW=((policy maker) or (policy makers) or policymaker*)) and((TI=research or AB=research) and(TI=priorit* or AB=priorit*))) or((TI=((research agenda) or (research agendas)) or AB=((research agenda) or (research agendas))) and(KW=setting)) (Copy Query)
221 Published Works results found
Date Range: | Earliest to 2011
Limited to: | English Only