# Acknowledgments

First, we express our sincere gratitude to the key informants who participated in the project. We thank our colleagues at the Oregon EPC, David Buckley, M.D., M.P.H., Carrie Patnode, Ph.D., M.P.H., and Evelyn Whitlock, M.D., M.P.H. for drafting the initial proposal for this project and an initial list of key informants. We thank Daphne Ann Plaut, M.L.S., A.H.I.P., for the initial literature scan, Rose Relevo, M.L.I.S., M.S., for literature searching and library assistance, Leah Williams, B.S., for editing assistance, and Joanna Siegel, R.N., S.M., S.D. for commenting on the draft report. Finally, we thank Mark Helfand, M.D., M.P.H., for his expertise and continued support.