# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CDC: Centers for Disease Control and Prevention
COI: Conflict of Interest
EPC: Evidence-based Practice Center
IOM: Institute of Medicine
KI: Key Informant
NIH: National Institutes of Health
TEP: Technical Expert Panel
VA: Veterans Affairs