# References

1 Clarke M. (2004). Doing new research? Don't forget the old. PLoS Med.
2 Clarke M, Chalmers I. (1998). Discussion sections in reports of controlled trials published in general medical journals: islands in search of continents?. JAMA.
3 Clarke M, Alderson P, Chalmers I. (2002). Discussion sections in reports of controlled trials published in general medical journals. JAMA.
4 Patsopoulos NA, Analatos AA, Ioannidis JP. (2005). Relative citation impact of various study designs in the health sciences. JAMA.
5 Greenberg D, Rosen AB, Wacht O, et al. (2010). A bibliometric review of cost-effectiveness analyses in the economic and medical literature: 1976–2006. Med Decis Making.
6 Barton GR, Briggs AH, Fenwick EA. (2008). Optimal cost-effectiveness decisions: the role of the cost-effectiveness acceptability curve (CEAC), the cost-effectiveness acceptability frontier (CEAF), and the expected value of perfection information (EVPI). Value Health.
7 Goeree R, O'Brien BJ, Blackhouse G, et al. (2002). Cost-effectiveness and cost-utility of long-term management strategies for heartburn. Value Health.
8 Blignault I, Ritchie J. (2009). Revealing the wood and the trees: reporting qualitative research. Health Promot J Austr.
9 Elliott R, Fischer CT, Rennie DL. (1999). Evolving guidelines for publication of qualitative research studies in psychology and related fields. Br J Clin Psychol.
10 Malterud K. (2001). Qualitative research: standards, challenges, and guidelines. Lancet.
11 Tong A, Sainsbury P, Craig J. (2007). Consolidated criteria for reporting qualitative research (COREQ): a 32-item checklist for interviews and focus groups. Int J Qual Health Care.
12 Drummond M, Manca A, Sculpher M. (2005). Increasing the generalizability of economic evaluations: recommendations for the design, analysis, and reporting of studies. Int J Technol Assess Health Care.
13 Nuijten MJ, Pronk MH, Brorens MJ, et al. (1998). Reporting format for economic evaluation. Part II: Focus on modelling studies. Pharmacoeconomics.
14 Ramsey S, Willke R, Briggs A, et al. (2005). Good research practices for cost-effectiveness analysis alongside clinical trials: the ISPOR RCT-CEA Task Force report. Value Health.
15 Siegel JE, Weinstein MC, Russell LB, et al. (1996). Recommendations for reporting cost-effectiveness analyses. Panel on Cost-Effectiveness in Health and Medicine. JAMA.