# Methods

We performed an empirical assessment of the reporting of recommendations for future research needs in secondary research publications (systematic reviews, cost-effectiveness analyses and VOI analyses).1 Systematic reviews, cost-effectiveness analyses and VOI analyses are ideally poised to identify and present future research needs because they draw on multiple information sources, use explicit methods to identify, appraise and synthesize research results,2,3 and are empirically known to have high impact on the conduct and interpretation of research.4

We also sought feedback from experts who are healthcare researchers, research funders, or payers in the form of open-ended interviews, to understand how familiar they are with evidence-based medicine and decision and economic analyses; how receptive they are to conclusions for future research needs that have been drawn from different methodologies (qualitative methods only, or combination of qualitative and quantitative methods); what reservations they have, if any; what information would the ideal future research needs document contain, and what minimum level of detail they would accept in terms of the recommendation itself (e.g., specificity by defining characteristics as per the PICO formalism) and the methodology it is based on (e.g., description of the process, model, assumptions). Based on the results of these explorations we provide preliminary guidance for presenting future research needs documents.

## Empirical Assessment of Evidence-based Documents

### Database Formation and Eligibility Criteria

We assembled a database of randomly selected systematic reviews that included quantitative evidence synthesis (meta-analysis) and cost-effectiveness (or cost-utility) analyses, published recently in selected medical journals, and of all published medical applications of VOI analyses we could identify. Appendix A provides details on our searches.

Specifically, we used computer-generated pseudorandom numbers to select 50 systematic reviews that included at least one meta-analysis of therapeutic interventions, published between 2005 and 2010 in the five general medical journals with the highest total annual citation count in 2009 according to Thompson ISI (New England Journal of Medicine, Journal of the American Medical Association, Annals of Internal Medicine, The Lancet, British Medical Journal). We considered eligible systematic reviews that had stated objectives, reported using a search strategy and predefined eligibility criteria for including studies, and included quantitative analyses (meta-analyses).

Cost-effectiveness or cost-utility analyses are most often published in specialty journals rather than in general medical journals. In addition to the aforementioned journals we considered cost-utility publications published in Pharmacoeconomics, International Journal of Technology Assessment in Health Care, and Medical Decision Making. Together with Annals of Internal Medicine and the Journal of the American Medical Association, these journals have published most cost-effectiveness analyses according to a recent bibliometric investigation.5 We selected at random 50 recent publications (between 2005 and 2010). We considered eligible cost-effectiveness or cost-utility analyses that explored patient-level clinical decisions (by enumerating available management strategies and their potential outcomes) and used appropriate quantitative methods to assign probabilities of occurrence and utility values to patient outcomes. We excluded analyses of resource allocation strategies, or of nonmedical public health interventions such as using mosquito nets for preventing malaria in underdeveloped countries.

Finally, we searched PubMed for English-language publications that applied VOI analyses in medical decision problems without any journal or date restrictions. We included methodology papers, provided that they also described applied analyses of the proposed methods in a probabilistic model that was parameterized using external data. As for cost-effectiveness and cost-utility analyses, we excluded VOI analyses of resource allocation strategies, or of nonmedical public health interventions. We also excluded VOI analyses that were based on data from a single clinical trial.

### Data Extraction

Four investigators extracted data in predefined forms. Forms were piloted in three papers to ensure that all investigators would extract data using the same operational criteria. From each eligible paper we recorded bibliographic information (first author name, title, year, journal, and country of publication). For systematic reviews with meta-analysis and for cost-effectiveness or cost-utility analyses we recorded if there was any discussion on the need for further research, and if yes, whether further research was recommended; whether suggestions for future research pertained to specific key questions of these studies; whether future research needs were discussed in a separate paragraph or section; whether methods for making research recommendations were clearly described, and if yes, what methods were used.

We extracted a different set of methodological and reporting characteristics from VOI papers, as they are tailored to address future research needs. Specifically, we extracted information on the decisional context including descriptions of populations, compared alternative strategies, perspective of analysis (societal, health care payer, other, or not stated), time horizon (yes/no, and months if the actual duration in months) and additional outcomes beyond monetary units (quality adjusted life expectancy, life expectancy, events of interest); type of intervention being studied (screening, other diagnostic, pharmaceutical, medical device, surgical, immunization, and other); whether the analysis pertained to prevention, and if yes what level (primary, secondary, tertiary); data sources used to parameterize models (nonsystematic review, systematic review, primary data, not stated); whether costs and effectiveness were discounted over time; and whether model predictions were calibrated or validated in independent datasets. We also recorded the type of sensitivity analyses used (one-way, two-way, multi-way, probabilistic), and the type of VOI calculations performed: expected value of perfect information (EVPI), expected value of partial perfect information (EVPPI), expected value of sample information (EVSI) or expected value of sample information for specific parameters (EVSI-P).^a^ We also recorded whether modeling accounted for the stochastic dependence between parameter distributions (operationally defined as using Markov chain Monte Carlo analyses versus not); and what type of graphs were used to describe VOI analysis results.

### Analysis

We generated frequency tables for the extracted items per types of publication. Whenever statistical comparisons are reported, they are based on nonparametric tests (Fisher’s exact test). Results are considered significant at the 0.05 level.^b^

## Qualitative Interviews

We performed semi-structured interviews to explore the experiences and opinions of four key informants (experts). Questions were open-ended, and were rephrased, as necessary, to elicit answers and themes.

### Research Team and Reflexivity

The interviews were conducted by the lead author, a researcher with experience in evidence-based medicine and decision science, and who also led a project on identifying future research needs pertinent to the comparison of percutaneous interventions and coronary artery bypass surgery in patients with coronary artery disease.

The interviewer had an established relationship with the interviewed experts prior to the commencement of the study, through their professional contact. In each interview both parties were familiar with each other’s background and research interests. Although the interviewer did not discuss or express his personal opinions on the questions at hand, the interviewed experts might have been able to guess the interviewer’s opinions based on their previous acquaintance. Given the established expertise of the individuals interviewed, we consider the possibility of “interviewer bias” to be minimal.

### Study Design and Analysis

The aim of the study was to understand what level of information on future research needs is most useful to potential users of future research needs documents, specifically health care researchers or decisionmaker scientists in a funding agency.

We used purposive sampling; that is, we invited experts because of their experience in health care, and because of their ability to provide complementary opinions and alternative viewpoints. We invited five experts to participate in the semi-structured interviews. Four participated, but the fifth did not respond to the invitation. Because very soon we reached saturation in terms of no longer identifying additional themes, we did not deem necessary to replace the fifth interviewer or to further expand the sample size. Experts still had profound disagreements on several of the initial issues, but did not bring up additional ones. Qualitative interviews are typically used to identify a range of themes, and not necessarily to reach a consensus (as is the goal of a Delphi process) or quantify frequencies of opinions (as is the goal with surveys).

One interview was conducted in person, and three over the telephone, with only the interviewer and the expert being present. The selected experts were all experienced in different aspects of health care research. The first expert is primarily a trialist who has designed and conducted several high impact trials in cardiovascular medicine, and who is also a practicing clinician. The second expert is a medical officer with the National Institute on Aging who also had long experience working in a major insurer. The third is a health care researcher with considerable experience in evidence-based medicine, health economics, and decision science, and is also a key member in a large professional organization (American College of Physicians). The fourth is key employee at the Center for Medicare and Medicaid Services. When applicable, in the description of the results we refer to experts as A, B, C and D. The correspondence of letters to experts is random and may or may not correspond to the order of presentation above.

The interviews followed a predefined series of questions, which had not been piloted in advance. Auxiliary material was available, including samples of statements describing future research needs in several topics, relevant tables with different layouts, and graphs. This material was referred to during the interviews on an as-needed basis, to facilitate descriptions or to elicit specific responses and reactions. The interviewer took notes but did not use any other type of recording (e.g., audio recording).

The interviewer identified themes after the end of each interview based on the discussions with the experts. No software was used to organize the derivation of themes. Both themes for which there was concordance and themes for which there was divergence of opinions between experts are described.

a A VOI analysis attempts to assign a value (usually a monetary amount) to the information that could be obtained by future research. The premise is that all decisions are made under uncertainty, which could be reduced using information obtained by further research. For example, a patient with coronary artery disease who needs revascularization can choose between percutaneous interventions and bypass surgery. However, the comparative effectiveness of the two interventions with respect to mortality, myocardial infarction, stroke, need for subsequent revascularizations, and the comparative safety of the interventions is not known with certainty. Either choice could be optimal or suboptimal for the particular patient, with different probabilities. The set of suboptimal choices represents the opportunity cost associated with the decision. The opportunity cost is high when there is a great deal of uncertainty around the decision, or low when the important decisional parameters are known with certainty. EVPI is an analysis that places an upper bound to this opportunity cost, or equivalently, an upper bound to the expected returns of future research. If EVPI is very low, then future research may not be necessary. EVPPI, refines the EVPI calculations by placing an upper bound to the value of research on specific (groups of) parameters. However, we will never be able to get perfect information; instead we can design studies that will reduce the uncertainty of current estimates. In order to examine specific designs, one can proceed to calculate EVSI, the expected value of information from a sample n (and compare it to the costs of performing actual studies).

b We did not perform extensive comparisons because many of the extracted items are subject to editorial requirements and space constraints.