# Discussion and Conclusions

Future research needs recommendations are valuable inputs for researchers, funders, and advocates making decisions about avenues for future scientific exploration. We performed an empirical evaluation of the published literature to appreciate the variability in the presentation of information on future research needs. We found that most systematic reviews, meta-analyses, or economic analyses do not focus on future research needs, and any referral to future research is most often cursory. Systematic reviews and meta-analyses often call for additional randomized trials, while economic analyses are more diverse in their suggestions.

In qualitative discussions with experts, we identified a number of general themes. The discussions were quickly saturated, and while additional one-to-one interviews could have generated more themes, it is unclear whether these would have been of major importance for defining the optimal format for presenting future research needs. An unanticipated theme from the qualitative interviews was that specificity in the recommendations for future research is not universally and unconditionally viewed as a desirable attribute. The rationale is that specific descriptions could be perceived as too prescriptive or restrictive, and in the extreme they may have unintended consequences, such as opposing the paradigm of investigator-initiated research. Experts disagreed on the importance of this point. Nevertheless it is probably prudent to take this point into account when reporting assessments of future research needs, and all experts agreed that proper framing of the future research needs documents could address this concern. A survey of a large and representative sample of potential users of future research needs assessments would clarify whether such reactions are prevalent. If yes, it would be also interesting to understand why some users are prone to seeing even moderately specific recommendations with skepticism. Ideology, cultural norms, or professional self-interests may be explanations.

Several limitations need to be considered when interpreting our results. First, we only recruited four experts for our qualitative interviews; hence, our results should be considered hypothesis forming and not representative of all stakeholders. However, the purpose of the qualitative interviews was to identify general themes with respect to the way different stakeholders would approach a document presenting and discussing future research needs, and not necessarily to get a representative quantification of different opinions. The optimal research design to quantify the frequency of different opinions is a survey using a representative sampling scheme, rather than qualitative interviews or even focus groups.

Regarding our empirical assessment of secondary research manuscripts, we focused on high impact general journals (for systematic reviews) or highly specialized technical journals (for cost-effectiveness/utility analyses). Thus our empirical assessment of future research presentation is not be generalizable to all journals. If anything, because even in these “top-tier” journals the presentation of implications for future research was fairly cursory and informal, the situation is unlikely to be better in other research outlets. Further, determining future research needs is not the primary focus of systematic reviews and cost-effectiveness/utility analyses. Therefore it is doubtful that including a broader set of journals would change the essence of our conclusions.

The concept of a stand-alone document on future research needs is probably new to most of the individuals approached, and additional discussion is likely needed regarding potential uses prior to making very specific recommendations on the optimal presentation of future research needs documents. We outline the following preliminary recommendations for presenting future research needs documents, based on the results of the empirical assessment and the qualitative interviews:

1. Provide succinct yet adequate description of methods and results, following guidelines for reporting of health care research (for example, reporting guidelines for qualitative research8–11 and modeling12–15). Aim for a level of detail similar to that found in papers addressed to a general medical audience.
2. Be cognizant of the importance of the face validity of the process. Justify the selection of the stakeholders who participated in the identification or prioritization of research needs, and be clear about their degree of engagement.
3. Consider reporting the results of the future research needs assessment at two levels of detail. A suggestion would be to first present general areas that merit future research without specifying research designs or specific details on, for example, PICO elements. A second set of results could elaborate further on potential research designs, details on PICO elements, or other details as applicable.
4. Frame the more specific set of results as “examples” rather than strict recommendations.
5. Avoid explicit prioritization of research needs when there are no clear differences in the perceived strength of alternative recommendations. A general prioritization of future research recommendations as of “high,” “medium,” or “low” importance may be more appropriate than an explicit numerical ranking. Consider a grouped presentation of future research needs by thematic entities.
6. Clearly define how the feasibility of future research was assessed. It may be instructive to perform power analyses for specific research designs for a range of assumptions, and to compare the results with the size and type of existing studies in the field. For example, trials are typically more resource-intensive than secondary analyses of existing data.