# Background

Systematic reviews of medical research often conclude by noting gaps in the evidence and sometimes recommending specific research to fill them in order to improve the evidence base for medical decisions. To encourage this process, the Effective Healthcare Program of the Agency for Healthcare Research and Quality (AHRQ) has introduced a new type of report, Future Research Needs, to assess the needs for future research in a specific topic after the completion of a systematic review of the evidence. After the completion of a comparative effectiveness review, EPCs would prioritize the identified evidence gaps into research needs, and suggest potential research designs. The premise is that not all evidence gaps are of equal importance, and because resources are finite, future research should address the most important among the answerable evidence gaps using the most efficient research methods. These assessments are summarized in “future research needs documents,” which are intended to inform and support researchers and those who fund research to ultimately enhance the body of comparative effectiveness evidence and maximize its usefulness for decisionmakers.

There are many possible ways to present recommendations about future research needs; the optimal presentation depends in the underlying methodology. Overall, one can distinguish between approaches that are based exclusively on qualitative research methods to elicit and synthesize the opinions of a group of stakeholders, and approaches that are a mix of qualitative and quantitative methods (such as decision, economic, or value of information [VOI] modeling). Obviously, such diverse types of information should be reported in different ways.

The purpose of this project is to determine an optimal format for presenting future research needs. In particular, we attempt to address the following questions that were determined by AHRQ: What level of specificity is needed by various funders or researchers for a research needs document to be informative? How can one categorize and present research needs? Is quantitative ranking of research recommendations helpful or an obstacle? What are the specific barriers to making a research needs document useful to researchers and funders?