# Appendix D Included and Excluded Studies for the Empirical Assessment of Value of Information Analyses

## Included Studies

PMID | Title | Year | Journal
6763124 | Decision-analytic determination of study size. The case of electronic fetal monitoring | 1981 | Med Decis Making
9357611 | Decision-analytic valuation of clinical information systems: application to an alerting system for coronary angiography | 1997 | Proc AMIA Annu Fall Symp
9456214 | Sensitivity analysis and the expected value of fperfect information | 1998 | Med Decis Making
9551284 | The cost-benefit of a randomized trial to a health care organization | 1998 | Control Clin Trials
11329844 | Bayesian value-of-information analysis. An application to a policy model of Alzheimer's disease | 2001 | Int J Technol Assess Health Care
12150601 | Markov chain Monte Carlo estimation of a multiparameter decision model: consistency of evidence and the accurate assessment of uncertainty | 2002 | Med Decis Making
12098524 | Planning the efficient allocation of research funds: an adapted application of a non-parametric Bayesian value of information analysis | 2002 | Health Policy
15248937 | A pilot study on the use of decision theory and value of information analysis as part of the NHS Health Technology Assessment programme | 2004 | Health Technol Assess
15215017 | Methods for expected value of information analysis in complex health economic models: developments on the health economics of interferon-beta and glatiramer acetate for multiple sclerosis | 2004 | Health Technol Assess
16076237 | Using value of information analysis to inform publicly funded research priorities | 2005 | Appl Health Econ Health Policy
16097842 | Economic evaluation of temozolomide in the treatment of recurrent glioblastoma multiforme | 2005 | Pharmacoeconomics
16022802 | Cost-effectiveness of alternative strategies for the initial medical management of non-ST elevation acute coronary syndrome: systematic review and decision-analytical modelling | 2005 | Health Technol Assess
16948891 | The cost-effectiveness of testing for hepatitis C in former injecting drug users | 2006 | Health Technol Assess
16997926 | An iterative Bayesian approach to health technology assessment: application to a policy of preoperative optimization for patients undergoing major elective surgery | 2006 | Med Decis Making
16545207 | Surveillance of Barrett's oesophagus: exploring the uncertainty through systematic review, expert workshop and economic modelling | 2006 | Health Technol Assess
16786498 | Informing the efficient use of health care and health care research resources - the case of screening for abdominal aortic aneurysm in Sweden | 2006 | Health Econ
16706572 | Comprehensive decision-analytic model and Bayesian value-of-information analysis: pentoxifylline in the treatment of chronic venous leg ulcers | 2006 | Pharmacoeconomics
16751321 | Implications of cancer staging uncertainties in radiation therapy decisions | 2006 | Med Decis Making
16984067 | Priority setting for research in health care: an application of value of information analysis to glycoprotein IIb/Illa antagonists in non-ST elevation acute coronary syndrome | 2006 | Int J Technol Assess Health Care
16707071 | The cost-effectiveness of screening for oral cancer in primary care | 2006 | Health Technol Assess
17887805 | A comparison of the cost effectiveness of pharmacotherapy or surgery (laparoscopic fundoplication) in the treatment of GORD | 2007 | Pharmacoeconomics
17651659 | Prenatal screening and treatment strategies to prevent group B streptococcal and other bacterial infections in early infancy: cost-effectiveness and expected value of information analyses | 2007 | Health Technol Assess
17848402 | Preventive strategies for group B streptococcal and other bacterial infections in early infancy: cost effectiveness and value of information analyses | 2007 | BMJ
17181985 | A systematic review and economic model of the clinical effectiveness and cost-effectiveness of docetaxel in combination with prednisone or prednisolone for the treatment of hormone-refractory metastatic prostate cancer | 2007 | Health Technol Assess
17579936 | Value of information analysis for a new technology: computer-assisted total knee replacement | 2007 | Int J Technol Assess Health Care
17999842 | The clinical effectiveness and cost-effectiveness of cardiac resynchronisation (biventricular pacing) for heart failure: systematic review and economic model | 2007 | Health Technol Assess
17493314 | Modeling payback from research into the efficacy of left- ventricular assist devices as destination therapy | 2007 | Int J Technol Assess Health Care
17493305 | Comparing the clinical and economic effects of clinical examination, pulse oximetry, and echocardiography in newborn screening for congenital heart defects: a probabilistic cost-effectiveness model and value of information analysis | 2007 | Int J Technol Assess Health Care
17720521 | Should hemodialysis patients with atrial fibrillation undergo systemic anticoagulation? A cost-utility analysis | 2007 | Am J Kidney Dis
18077847 | Cost-effectiveness of alternative outpatient pelvic inflammatory disease treatment strategies | 2007 | Sex Transm Dis
17261117 | Economic evaluation of palliative management versus peritoneal dialysis and hemodialysis for end-stage renal disease: evidence for coverage decisions in Thailand | 2007 | Value Health
18263560 | Identifying research priorities: the value of information associated with repeat screening for age-related macular degeneration | 2008 | Med Decis Making
18513466 | The clinical effectiveness and cost-effectiveness of screening programmes for amblyopia and strabismus in children up to the age of 4-5 years: a systematic review and economic evaluation | 2008 | Health Technol Assess
18179675 | Uncertainty in decision-making: value of additional information in the cost-effectiveness of lifestyle intervention in overweight and obese people | 2008 | Value Health. 2008 May–Jun;11(3):424–34. Epub 2007 Dec 17.
18796263 | The effectiveness and cost-effectiveness of minimal access surgery amongst people with gastro-oesophageal reflux disease - a UK collaborative study. The REFLUX trial | 2008 | Health Technol Assess
18522663 | Decision-Analytic Modeling to Assist Decision Making in Organizational Innovation: The Case of Shared Care in Hearing Aid Provision | 2008 | Health Serv Res
19036232 | Curative catheter ablation in atrial fibrillation and typical atrial flutter: systematic review and economic evaluation | 2008 | Health Technol Assess
18380636 | Gaussian process metamodeling in Bayesian value of information analysis: a case of the complex health economic model for breast cancer screening | 2008 | Value Health
18272361 | Surveillance of Barrett's oesophagus: is it worthwhile? | 2008 | Eur J Cancer
18380629 | Cost-effectiveness and value of information analyses of neuraminidase inhibitors for the treatment of influenza | 2008 | Value Health
19178122 | Statin therapy in rheumatoid arthritis: a cost-effectiveness and value-of-information analysis | 2009 | Pharmacoeconomics
19903416 | The clinical effectiveness of glucosamine and chondroitin supplements in slowing or arresting progression of osteoarthritis of the knee: a systematic review and economic evaluation | 2009 | Health Technol Assess
18647257 | The potential clinical and economic outcomes of pharmacogenomic approaches to EGFR-tyrosine kinase inhibitor therapy in non-small-cell lung cancer | 2009 | Value Health
19553267 | Analysis of cost effectiveness of screening Danish men aged 65 for abdominal aortic aneurysm | 2009 | BMJ
19789242 | Value-of-information analysis to guide future research in colorectal cancer screening | 2009 | Radiology
19332851 | Impact of whole-body CT screening on the cost- effectiveness of CT colonography | 2009 | Radiology
19624978 | Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis | 2009 | Health Technol Assess
18657098 | Value of information and value of implementation: application of an analytic framework to inform resource allocation decisions in metastatic hormone-refractory prostate cancer | 2009 | Value Health
19558190 | Informing disinvestment through cost-effectiveness modelling: is lack of data a surmountable barrier? | 2009 | Appl Health Econ Health Policy
19409154 | Enhanced external counterpulsation for the treatment of stable angina and heart failure: a systematic review and economic analysis | 2009 | Health Technol Assess
19908924 | Cost effectiveness of herpes zoster vaccine in Canada | 2009 | Pharmacoeconomics
19207559 | Economic analysis of esophageal stenting for management of malignant dysphagia | 2009 | Dis Esophagus
19573471 | The effect of different treatment durations of clopidogrel in patients with non-ST-segment elevation acute coronary syndromes: a systematic review and value of information analysis | 2009 | Health Technol Assess
19509121 | The cost-effectiveness of an RCT to establish whether 5 or 10 years of bisphosphonate treatment is the better duration for women with a prior fracture | 2009 | Med Decis Making
19539109 | Results of a model analysis to estimate cost utility and value of information for intravenous immunoglobulin in Canadian adults with chronic immune thrombocytopenic purpura | 2009 | Clin Ther
20190188 | Uncertainty and patient heterogeneity in medical decision models | 2010 | Med Decis Making
20303217 | The cost-effectiveness of particle therapy in non-small cell lung cancer: Exploring decision uncertainty and areas for future research | 2010 | Cancer Treat Rev
20087087 | Value-of-information analysis to guide future research in the management of the colorectal malignant polyp | 2010 | Dis Colon Rectum
19084367 | The value of positron emission tomography in patients with non-small cell lung cancer | 2010 | Eur J Radiol
20492762 | A systematic review and economic evaluation of the clinical effectiveness and cost-effectiveness of aldosterone antagonists for postmyocardial infarction heart failure | 2010 | Health Technol Assess
20093524 | Minor head injury: CT-based strategies for management-- a cost-effectiveness analysis | 2010 | Radiology
20627875 | Trabectedin in the treatment of metastatic soft tissue sarcoma: cost-effectiveness, cost-utility and value of information | 2010 | Ann Oncol
20375420 | The Cost-Effectiveness of a Randomized Controlled Trial to Establish the Relative Efficacy of Vitamin K1 Compared with Alendronate | 2010 | Med Decis Making.
20384978 | The Cost-Effectiveness of Group Cognitive Behavioral Therapy Compared with Routine Primary Care for Women with Postnatal Depression in the UK | 2010 | Value Health
20430289 | Cost-effectiveness of breech version by acupuncture-type interventions on BL 67, including moxibustion, for women with a breech foetus at 33 weeks gestation: a modelling approach | 2010 | Complement Ther Med
20035545 | Cost-utility and value-of-information analysis of early versus delayed laparoscopic cholecystectomy for acute cholecystitis | 2010 | Br J Surg

## Excluded Studies

PMID | Title | Year | Journal
16589926 | MEASURES OF THE VALUE OF INFORMATION | 1956 | Proc Natl Acad Sci
5990730 | [Value of information of kidney biopsy] | 1966 | Z Gesamte Inn Med
1197296 | The price and value of information | 1975 | Proc R Soc Med
682303 | Assessment of value of information for patients | 1978 | JAMA
12266151 | An economic analysis of marital fertility: some notes | 1981 | Philipp Econ J
10267433 | Information resources management: management focus on the value of information and information work | 1984 | J Inf Image Manage
10269803 | Regulating uncertain health hazards when there is changing risk information | 1984 | J Health Econ
3831639 | Maximum Shannon information content of diagnostic medical testing. Including application to multiple non- independent tests | 1985 | Med Decis Making
3882734 | Treatment selection for cancer patients: application of statistical decision theory to the treatment of advanced ovarian cancer | 1985 | J Chronic Dis
3727069 | [The value of information obtained from preoperative laboratory parameters in patients receiving elective surgery] | 1986 | Ugeskr Laeger
3597686 | What's wrong with decision analysis? Can the left brain influence the right? | 1987 | J Chronic Dis
10301458 | Capital expenditure planning: the value of information to hospitals | 1987 | Hosp Health Serv Adm
3185180 | Focusing technology assessment using medical decision theory | 1988 | Med Decis Making
2646176 | Full threshold versus quantification of defects for visual field testing in glaucoma | 1989 | Graefes Arch Clin Exp Ophthalmol
2792592 | Statistical uncertainty in the no-observed-adverse-effect level | 1989 | Fundam Appl Toxicol
2112217 | Targeting assessments of magnetic resonance imaging in suspected multiple sclerosis | 1990 | Med Decis Making
2115175 | Value-of-information analysis of testing strategies: estimating the effect of uncertainty about the proportion of chemicals that are true human carcinogens | 1990 | Prog Clin Biol Res
2119006 | Comparing the cost of spinal MR with conventional myelography and radiculography | 1990 | Neuroradiology
2196411 | Judicial and legislative viewpoints on physician misestimation of patient dysutilities: a problem for decision analysts | 1990 | Med Decis Making
1487587 | Decision analysis for periodontal therapy | 1992 | J Dent Educ
1538631 | A pitfall in utility assessment--patients' undisclosed investment decisions | 1992 | Med Decis Making
1631608 | To prescribe or not to prescribe: on the regulation of pharmaceuticals in less developed countries | 1992 | Soc Sci Med
8234948 | The value of animal test information in environmental control decisions | 1993 | Risk Anal
10123827 | Integrating capital budgeting techniques | 1993 | Health Care Strateg Manage
10129155 | Creating a market: an economic analysis of the purchaser- provider model | 1993 | Health Policy
7942098 | Differences in the value of clinical information: referring physicians versus consulting specialists | 1994 | J Am Board Fam Pract
7950082 | Improving outpatient services--the value of information | 1994 | Proc Annu Symp Comput Appl Med Care
7964217 | The value of risk-reducing information | 1994 | J Med Syst
7990173 | Experimental design for parameter estimation through sensitivity analysis | 1994 | J Toxicol Environ Health
8187733 | Statistical issues on the no-observed-adverse-effect level in categorical response | 1994 | Environ Health Perspect
7546223 | Predictions of rodent carcinogenicity testing results: interpretation in light of the Lave-Omenn value-of- information model | 1995 | Mol Carcinog
7860318 | Understanding the factors behind the decision to purchase varying coverage amounts of long-term care insurance | 1995 | Health Serv Res
8733196 | A cost-benefit analysis of voluntary routine HIV-antibody testing for hospital patients | 1996 | Soc Sci Med
8783436 | Regret graphs, diagnostic uncertainty and Youden's Index | 1996 | Stat Med
8868224 | Risk-based environmental remediation: Bayesian Monte Carlo analysis and the expected value of sample information | 1996 | Risk Anal
8913550 | Comparing and using assessments of the value of information to clinical decision-making | 1996 | Bull Med Libr Assoc
8934123 | Outcomes research and cost-effectiveness analysis in radiology | 1996 | Eur Radiol
9003938 | An economic approach to clinical trial design and research priority-setting | 1996 | Health Econ
9087883 | Optimum investments in project evaluations: when are cost-effectiveness analyses cost-effective? | 1996 | J Med Syst
10162540 | Evaluating methodologies for assessing the value of information: sifting the evidence | 1996 | Top Health Inf Manage
10172597 | Applying the value-of-information paradigm to laboratory management | 1996 | Clin Lab Manage Rev
9333085 | Cost-effectiveness analysis of treatment alternatives for beef bulls with preputial prolapse | 1997 | J Am Vet Med Assoc
9357709 | A decision analytic method for scoring performance on computer-based patient simulations | 1997 | Proc AMIA Annu Fall Symp
10169100 | Genetic information and investment in human capital | 1997 | J Health Econ
9520961 | Assessing the value of a new pharmaceutical. A feasibility study of contingent valuation in managed care | 1998 | Med Care.
9554104 | Quantitative information of specific diagnostic tests | 1998 | J Med Syst
9564416 | The value of information and the cost of uncertainty: who pays the bill? | 1998 | Angle Orthod
9708589 | The impact of risk information on patients' willingness to pay for autologous blood donation | 1998 | Med Care
9753380 | Risk adjustment and the trade-off between efficiency and risk selection: an application of the theory of fair compensation | 1998 | Health Econ
10186453 | Cost-of-illness studies. Useful for health policy? | 1998 | Pharmacoeconomics
10348422 | Bayesian approaches to the value of information: implications for the regulation of new pharmaceuticals | 1999 | Health Econ
10538846 | Benefits foregone: too much of the wrong and too little of the right. Based on a presentation by Bernard S. Bloom, PhD | 1999 | Am J Manag Care
10548220 | Discriminant power and information content of Ranson's prognostic signs in acute pancreatitis: a meta-analytic study | 1999 | Crit Care Med
10566413 | Scoring performance on computer-based patient simulations: beyond value of information | 1999 | Proc AMIA Symp
10765446 | Adaptive spatial sampling of contaminated soil | 1999 | Risk Anal
11844400 | Menu Analysis for Improved Customer Demand and Profitability in Hospital Cafeterias | 1999 | Can J Diet Pract Res
10795342 | Risk estimation and value-of-information analysis for three proposed genetic screening programs for chronic beryllium disease prevention | 2000 | Risk Anal
11148867 | Addressing uncertainty in medical cost-effectiveness analysis implications of expected utility maximization for methods to perform sensitivity analysis and the use of cost- effectiveness analysis to set priorities for medical research | 2001 | J Health Econ
11332553 | Estimation of error and bias in Bayesian Monte Carlo decision analysis using the bootstrap | 2001 | Risk Anal
11558649 | A dynamic programming approach to the efficient design of clinical trials | 2001 | J Health Econ. 2001
11695561 | Assessment of human cancer risk: challenges for alternative approaches | 2001 | Toxicol Pathol
11916800 | How to schedule elective surgical cases into specific operating rooms to maximize the efficiency of use of operating room time | 2002 | Anesth Analg
11918821 | The bias against new innovations in health care: value uncertainty and willingness to pay | 2002 | Value Health
12002189 | Quantification of variability and uncertainty in lawn and garden equipment NOx and total hydrocarbon emission factors | 2002 | J Air Waste Manag Assoc
19807328 | Decision analysis and drug development portfolio management: uncovering the real options value of your projects | 2002 | Expert Rev Pharmacoecon Outcomes Res
12568827 | Using decision analytic methods to assess the utility of family history tools | 2003 | Am J Prev Med
14499052 | The role of modelling in prioritising and planning clinical trials | 2003 | Health Technol Assess
14554141 | Simulation modeling to derive the value-of-information for risky animal disease-import decisions | 2003 | Prev Vet Med
14601158 | Estimating the marginal value of 'better' research output: 'designed' versus 'routine' data in randomised controlled trials | 2003 | Health Econ
14984281 | The use of decision models in mental health economic evaluation: challenges and opportunities | 2003 | Appl Health Econ Health Policy
19807372 | Bayesian approach in pharmacoeconomics: relevance to decision-makers | 2003 | Expert Rev Pharmacoecon Outcomes Res
15090106 | Expected value of sample information calculations in medical decision modeling | 2004 | Med Decis Making
15112789 | Learning as an objective within a structured risk management decision process | 2004 | Environ Sci Technol
15155018 | Value of information literature analysis: a review of applications in health risk management | 2004 | Med Decis Making
15209935 | Value of information analysis in environmental health risk management decisions: past, present, and future | 2004 | Risk Anal
15356229 | Forecasting the number of soil samples required to reduce remediation cost uncertainty | 2004 | J Environ Qual
15484602 | Setting priorities for research | 2004 | Health Policy
15633986 | A probabilistic and interactive decision-analysis system for unruptured intracranial aneurysms | 2004 | Neurosurg Focus
15660617 | Tiered chemical testing: a value of information approach | 2004 | Risk Anal
15688986 | Precautionary principles: a jurisdiction-free framework for decision-making under risk | 2004 | Hum Exp Toxicol
15386668 | The role of consumer knowledge of insurance benefits in the demand for preventive health care among the elderly | 2005 | Health Econ
15647219 | When is evidence sufficient? | 2005 | Health Aff (Millwood)
15693724 | Role of pharmacoeconomic analysis in R&D decision making: when, where, how? | 2005 | Pharmacoeconomics
15700300 | Information and sorting in the market for obstetrical services | 2005 | Health Econ
15787767 | Research strategies for magnetic fields and cancer | 2005 | Risk Anal
15806619 | The value of information and optimal clinical trial design | 2005 | Stat Med
15876209 | Additivity of information value in two-act linear loss decisions with normal priors | 2005 | Risk Anal
16046019 | The value of genetic information in selecting dairy replacements | 2005 | Prev Vet Med
16091019 | Establishing the cost-effectiveness of new pharmaceuticals under conditions of uncertainty--when is there sufficient evidence? | 2005 | Value Health
16268932 | Optimal tracking and testing of U.S. and Canadian herds for BSE: a value-of-information (VOI) approach | 2005 | Risk Anal
16433092 | Integrating seasonal climate prediction and agricultural models for insights into agricultural practice | 2005 | Philos Trans R Soc Lond B Biol Sci
16639994 | The application of special technologies in diagnostic anatomic pathology: is it consistent with the principles of evidence-based medicine? | 2005 | Semin Diagn Pathol
16389669 | Identifying key parameters in cost-effectiveness analysis using value of information: a comparison of methods | 2006 | Health Econ
16389671 | A Bayesian approach to analysing the cost-effectiveness of two primary care interventions aimed at improving attendance for breast screening | 2006 | Health Econ
16539993 | [Probabilistic cost-effectiveness analysis of the treatment of sleep apnea] | 2006 | Gac Sanit
16652389 | The economics of diagnosis | 2006 | Health Econ
16753098 | [The value of information and information as a value] | 2006 | Gac Sanit
17059697 | Estimating the value of information in strategies for identifying patients at high risk of cardiovascular disease | 2006 | Inform Prim Care
17067191 | Using value of information analysis to prioritise health research: some lessons from recent UK experience | 2006 | Pharmacoeconomics
17067194 | Analysis sans frontieres: can we ever make economic evaluations generalisable across jurisdictions? | 2006 | Pharmacoeconomics
17184397 | Global surveillance and the value of information: the case of the global polio laboratory network | 2006 | Risk Anal
16945438 | Efficient computation of partial expected value of sample information using Bayesian approximation | 2007 | J Health Econ
16981193 | Expected value of information and decision making in HTA | 2007 | Health Econ
17327242 | Sample-size calculations for trials that inform individual treatment decisions: a 'true-choice' approach | 2007 | Clin Trials
17328046 | Expected value of sample information for Weibull survival data | 2007 | Health Econ
17328053 | Setting priorities for research: a practical application of 'payback' and expected value of information | 2007 | Health Econ
17367372 | Rapid humanitarian assessments and rationality: a value- of-information study from Iraq, 2003–04 | 2007 | Disasters
17409361 | Limitations of acceptability curves for presenting uncertainty in cost-effectiveness analysis | 2007 | Med Decis Making
17409362 | Value of information on preference heterogeneity and individualized care | 2007 | Med Decis Making
17676057 | Learning the value of information in an uncertain world | 2007 | Nat Neurosci
17715257 | Clinical decision making and the expected value of information | 2007 | Clin Trials
17761960 | Calculating partial expected value of perfect information via Monte Carlo sampling algorithms | 2007 | Med Decis Making
17901602 | The value of information for decision-making in the healthcare environment | 2007 | Stud Health Technol Inform
17985703 | Value of information analysis in remedial investigations | 2007 | Ambio
18229486 | The role of experience in decisions from description | 2007 | Psychon Bull Rev
17638032 | Estimating the expected value of partial perfect information: a review of methods | 2008 | Eur J Health Econ
17764096 | Cost-effectiveness analysis of a multinational RCT with a binary measure of effectiveness and an interacting covariate | 2008 | Health Econ
17767994 | Learning-by-catching: uncertain invasive-species populations and the value of information | 2008 | J Environ Manage
17854433 | Assessing the impact of censoring of costs and effects on health-care decision-making: an example using the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study | 2008 | Value Health
18179665 | Time and expected value of sample information wait for no patient | 2008 | Value Health
18218176 | Value of information of a clinical prediction rule: informing the efficient use of healthcare and health research resources | 2008 | Int J Technol Assess Health Care
18227539 | Value of information analysis used to determine the necessity of additional research: MR imaging in acute knee trauma as an example | 2008 | Radiology
18263559 | The value of implementation and the value of information: combined and uneven development | 2008 | Med Decis Making
18356312 | Health technology assessment in the cost-disutility plane | 2008 | Med Decis Making
18368045 | Choice, uncertainty and value in prefrontal and cingulate cortex | 2008 | Nat Neurosci
18438203 | A forensic evaluation of the National Emphysema Treatment Trial using the expected value of information approach | 2008 | Med Care
18448701 | The half-life of truth: what are appropriate time horizons for research decisions? | 2008 | Med Decis Making
18480035 | The option value of delay in health technology assessment | 2008 | Med Decis Making
18489513 | Optimal cost-effectiveness decisions: the role of the cost- effectiveness acceptability curve (CEAC), the cost- effectiveness acceptability frontier (CEAF), and the expected value of perfection information (EVPI) | 2008 | Value Healt
18539311 | Assessment of the value of reducing uncertainty by sampling in a groundwater remediation system | 2008 | Sci Total Environ
18697843 | Determining optimal sample sizes for multi-stage randomized clinical trials using value of information methods | 2008 | Clin Trials
18806189 | Decision analysis for resource allocation in health care | 2008 | J Health Serv Res Policy
18998811 | Value of information in virtual patient performance evaluations | 2008 | AMIA Annu Symp Proc
18998813 | Value of information in virtual patients portraying pharyngitis | 2008 | AMIA Annu Symp Proc
19025425 | Prioritizing future research on off-label prescribing: results of a quantitative evaluation | 2008 | Pharmacotherapy
19029207 | Optimal sample size determinations from an industry perspective based on the expected value of information | 2008 | Clin Trials
19602213 | Expected value of perfect information: an empirical example of reducing decision uncertainty by conducting additional research | 2008 | Value Health
18435429 | Globally optimal trial design for local decision making | 2009 | Health Econ
18524652 | Costs of back pain in Germany | 2009 | Eur J Pain
18804324 | Assessing the value of information for water quality management in the North Sea | 2009 | J Environ Manage
19150015 | [Cost-effectiveness analysis of a genetic screening program in the close relatives of Spanish patients with familial hypercholesterolemia] | 2009 | Rev Esp Cardiol
19394574 | Health technology assessment and primary data collection for reducing uncertainty in decision making | 2009 | J Am Coll Radiol
19432841 | Enhancing value of information analyses | 2009 | Value Health
19509337 | Multidimensional evaluation of managed relocation | 2009 | Proc Natl Acad Sci
19657882 | The use and value of information systems as evaluated by dairy and specialty crop farm managers | 2009 | J Agromedicine
19694535 | Quantifying the adaptive value of learning in foraging behavior | 2009 | Am Nat
19712008 | A decision-theoretic framework for the application of cost- effectiveness analysis in regulatory processes | 2009 | Pharmacoeconomics
19762100 | Risk-based sample size calculation for consecutive surveys to document freedom from animal diseases | 2009 | Prev Vet Med
19816524 | Propaganda, Public Information, and Prospecting: Explaining the Irrational Exuberance of Central Place Foragers During a Late Nineteenth Century Colorado Silver Rush | 2009 | Hum Ecol Interdiscip J
19816857 | Investment in antiviral drugs: a real options approach | 2009 | Health Econ
19399753 | Optimal clinical trial design using value of information methods with imperfect implementation | 2010 | Health Econ
19688780 | Cost-effectiveness acceptability curves--caveats quantified | 2010 | Health Econ
19818058 | Value of information analyses of economic randomized controlled trials: the treatment of intermittent claudication | 2010 | Value Health
19903571 | Economic valuation of environmental benefits from wastewater treatment processes: an empirical approach for Spain | 2010 | Sci Total Environ
20022648 | Modelling collective effectiveness of voluntary vaccination with and without incentives | 2010 | Prev Vet Med
20035544 | Commentary on Cost-utility and value-of-information analysis of early versus delayed laparoscopic cholecystectomy for acute cholecystitis (Br J Surg 2010; 97: 210–219) | 2010 | Br J Surg.
20040743 | Exploring the research decision space: the expected value of information for sequential research designs | 2010 | Med Decis Making
20085386 | Can't get no satisfaction? Will pay for performance help?: toward an economic framework for understanding performance-based risk-sharing agreements for innovative medical products | 2010 | Pharmacoeconomics
20107161 | Researchers consider value-of-information theory for selecting trials | 2010 | J Natl Cancer Inst
20307281 | Current sample size conventions: flaws, harms, and alternatives | 2010 | BMC Med
20366697 | Time walkers and spatial dynamics of aging information | 2010 | Phys Rev Lett
20378190 | Simulation sample sizes for Monte Carlo partial EVPI calculations | 2010 | J Health Econ
20392316 | Study of progesterone for the prevention of preterm birth in twins (STOPPIT): findings from a trial-based cost-effectiveness analysis | 2010 | Int J Technol Assess Health Care
20455926 | Controlling established invaders: integrating economics and spread dynamics to determine optimal management | 2010 | Ecol Lett
20525915 | Experience matters: information acquisition optimizes probability gain | 2010 | Psychol Sci
20629473 | The Value of Value of Information: Best Informing Research Design and Prioritization Using Current Methods | 2010 | Pharmacoeconomics
20632291 | Cost-utility and value-of-information analysis of early versus delayed laparoscopic cholecystectomy for acute cholecystitis (Br J Surg 2010; 97: 210–219) | 2010 | Br J Surg