# Appendix C Included and Excluded Studies for the Empirical Assessment of Cost-Effectiveness Analyses

## Included Studies

PMID | Title | Year | Journal
19638648 | Options for managing low grade cervical abnormalities detected at screening: cost effectiveness study | 2009 | BMJ
20059782 | Cost-effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers in newly diagnosed type 2 diabetes in Germany | 2010 | Int J Technol Assess Health Care
19354343 | Cost-effectiveness evaluation of a quadrivalent human papillomavirus vaccine in Belgium | 2009 | Pharmacoeconomics
19372131 | Surgical treatments for men with benign prostatic enlargement: cost effectiveness study | 2009 | BMJ
19690341 | Lifestyle interventions for knee pain in overweight and obese adults aged > or = 45: economic evaluation of randomised controlled trial | 2009 | BMJ
17192116 | Cost effectiveness of a pharmacy-based coaching programme to improve adherence to antidepressants | 2007 | Pharmacoeconomics
20550222 | Impact of rapid methicillin-resistant Staphylococcus aureus polymerase chain reaction testing on mortality and cost effectiveness in hospitalized patients with bacteraemia: a decision model | 2010 | Pharmacoeconomics
17848402 | Preventive strategies for group B streptococcal and other bacterial infections in early infancy: cost effectiveness and value of information analyses | 2007 | BMJ
17937835 | Economic evaluation of laparoscopic surgery for colorectal cancer | 2007 | Int J Technol Assess Health Care
18310262 | Helicobacter pylori test and treat versus proton pump inhibitor in initial management of dyspepsia in primary care: multicentre randomised controlled trial (MRC-CUBE trial) | 2008 | BMJ
16460137 | The long-term cost effectiveness of treatments for benign prostatic hyperplasia | 2006 | Pharmacoeconomics
16571195 | Early assessment of the likely cost-effectiveness of a new technology: A Markov model with probabilistic sensitivity analysis of computer-assisted total knee replacement | 2006 | Int J Technol Assess Health Care
18708248 | Improved oxygen systems for childhood pneumonia: a multihospital effectiveness study in Papua New Guinea | 2008 | Lancet
17350965 | Parenting programme for parents of children at risk of developing conduct disorder: cost effectiveness analysis | 2007 | BMJ
19331707 | Microvolt T-wave alternans and the selective use of implantable cardioverter defibrillators for primary prevention: a cost-effectiveness study | 2009 | Int J Technol Assess Health Care
16920473 | Cardiovascular disease prevention with a multidrug regimen in the developing world: a cost-effectiveness analysis | 2006 | Lancet
20584354 | The cost-effectiveness of the SPHERE intervention for the secondary prevention of coronary heart disease | 2010 | Int J Technol Assess Health Care
16365467 | Empirical anti-Candida therapy among selected patients in the intensive care unit: a cost-effectiveness analysis | 2005 | Ann Intern Med
19757866 | Head lice treatments and school policies in the US in an era of emerging resistance: a cost-effectiveness analysis | 2009 | Pharmacoeconomics
18936502 | Cost-effectiveness of nurse-led disease management for heart failure in an ethnically diverse urban community | 2008 | Ann Intern Med
18400123 | Cost-effectiveness of a multidisciplinary fall prevention program in community-dwelling elderly people: a randomized controlled trial (ISRCTN 64716113) | 2008 | Int J Technol Assess Health Care
20133502 | Economic evaluation of the DiAMOND randomized trial: cost and outcomes of 2 decision aids for mode of delivery among women with a previous cesarean section | 2010 | Med Decis Making
18782838 | Paracetamol plus ibuprofen for the treatment of fever in children (PITCH): economic evaluation of a randomised controlled trial | 2008 | BMJ
16673687 | Value of magnetic resonance cholangiopancreatography in the diagnosis of biliary abnormalities in postcholecystectomy patients: a probabilistic cost-effectiveness analysis of diagnostic strategies | 2006 | Int J Technol Assess Health Care
17909207 | Cost-effectiveness of screening and vaccinating Asian and Pacific Islander adults for hepatitis B | 2007 | Ann Intern Med
16740528 | Pressure relieving support surfaces (PRESSURE) trial: cost effectiveness analysis | 2006 | BMJ
16984065 | Economic evaluation of empirical antisecretory therapy versus Helicobacter pylori test for management of dyspepsia: a randomized trial in primary care | 2006 | Int J Technol Assess Health Care
20406865 | Cost effectiveness of home ultraviolet B phototherapy for psoriasis: economic evaluation of a randomised controlled trial (PLUTO study) | 2010 | BMJ
18063025 | Prevention of cardiovascular disease in high-risk individuals in low-income and middle-income countries: health effects and costs | 2007 | Lancet
18199700 | The impact of response to the results of diagnostic tests for malaria: cost-benefit analysis | 2008 | BMJ
17638858 | Diagnostic accuracy and clinical utility of a simplified low cost method of counting CD4 cells with flow cytometry in Malawi: diagnostic accuracy study | 2007 | BMJ
20392321 | Cost-effectiveness of enhanced external counterpulsation (EECP) for the treatment of stable angina in the United Kingdom | 2010 | Int J Technol Assess Health Care
20014877 | A policy model to evaluate the benefits, risks and costs of warfarin pharmacogenomic testing | 2010 | Pharmacoeconomics
16525173 | Cost-effectiveness of osteoporosis screening and treatment with hormone replacement therapy, raloxifene, or alendronate | 2006 | Med Decis Making
16984069 | Cost-effectiveness analysis of strategies for HER2 testing of breast cancer patients in France | 2006 | Int J Technol Assess Health Care
19126247 | Cost-effectiveness of magnetic resonance guided focused ultrasound for the treatment of uterine fibroids | 2009 | Int J Technol Assess Health Care
17960953 | Strategies for the management of suspected heparin-induced thrombocytopenia: a cost-effectiveness analysis | 2007 | Pharmacoeconomics
20028779 | Screening for postnatal depression in primary care: cost effectiveness analysis | 2009 | BMJ
16980315 | A randomised controlled trial of acupuncture care for persistent low back pain: cost effectiveness analysis | 2006 | BMJ
18793033 | Costs and effects of secondary prevention with perindopril in stable coronary heart disease in Poland: an analysis of the EUROPA study including 1251 Polish patients | 2008 | Pharmacoeconomics
19331713 | Can calcium chemoprevention of adenoma recurrence substitute or serve as an adjunct for colonoscopic surveillance? | 2009 | Int J Technol Assess Health Care
18218176 | Value of information of a clinical prediction rule: informing the efficient use of healthcare and health research resources | 2008 | Int J Technol Assess Health Care
17129076 | Cost effectiveness of tumour necrosis factor-alpha inhibitors as first-line agents in rheumatoid arthritis | 2006 | Pharmacoeconomics
17488139 | Economic evaluation of treatment administration strategies of ganciclovir for cytomegalovirus retinitis in HIV/AIDS patients in Thailand: a simulation study | 2007 | Pharmacoeconomics
19366497 | Cost-effectiveness of human papillomavirus vaccination in Belgium: do not forget about cervical cancer screening | 2009 | Int J Technol Assess Health Care
19620143 | When to start antiretroviral therapy in resource-limited settings | 2009 | Ann Intern Med
20194233 | Cost-effectiveness of preparticipation screening for prevention of sudden cardiac death in young athletes | 2010 | Ann Intern Med
20446755 | Cost effectiveness of leukotriene receptor antagonists versus long-acting beta-2 agonists as add-on therapy to inhaled corticosteroids for asthma: a pragmatic trial | 2010 | Pharmacoeconomics
20550224 | Cost effectiveness of leukotriene receptor antagonists versus inhaled corticosteroids for initial asthma controller therapy: a pragmatic trial | 2010 | Pharmacoeconomics
17887807 | Cost effectiveness of pegaptanib for the treatment of age-related macular degeneration in the UK | 2007 | Pharmacoeconomics

## Excluded Studies

PMID | Title | Year | Journal
20465313 | Cetuximab for recurrent and/or metastatic squamous cell carcinoma of the head and neck: a NICE single technology appraisal. | 2010 | Pharmacoeconomics
18400122 | Cost-effectiveness of primarily human papillomavirus-based cervical cancer screening in settings with currently established Pap screening: a systematic review commissioned by the German Federal Ministry of Health. | 2008 | IJTAHC
20059778 | Prognostic value, clinical effectiveness, and cost-effectiveness of high-sensitivity C-reactive protein as a marker for major cardiac events in asymptomatic individuals: a health technology assessment report. | 2010 | IJTAHC
19640014 | How to deal with cost differences at baseline. | 2009 | Pharmacoeconomics
16984676 | Cost-effectiveness of self-management in asthma: a systematic review of peak flow monitoring interventions. | 2006 | IJTAHC