# Appendix B Included and Excluded Studies for the Empirical Assessment of Systematic Reviews

## Included Studies

PMID | Title | Year | Journal
17622601 | Efficacy and safety of incretin therapy in type 2 diabetes: systematic review and meta-analysis | 2007 | JAMA
19509383 | Corticosteroids in the treatment of severe sepsis and septic shock in adults: a systematic review | 2009 | JAMA
17662881 | Recurrence rates of video-assisted thoracoscopic versus open surgery in the prevention of recurrent pneumothoraces: a systematic review of randomised and non-randomised trials | 2007 | Lancet
19436018 | Aspirin for the prevention of cardiovascular events in patients with peripheral artery disease: a meta-analysis of randomized trials | 2009 | JAMA
16418466 | Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials | 2006 | JAMA
18313501 | Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis | 2008 | Lancet
20671013 | Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis | 2010 | BMJ
16705109 | Anti-TNF antibody therapy in rheumatoid arthritis and the risk of serious infections and malignancies: systematic review and meta-analysis of rare harmful effects in randomized controlled trials | 2006 | JAMA
20197533 | Higher vs lower positive end-expiratory pressure in patients with acute lung injury and acute respiratory distress syndrome: systematic review and meta-analysis | 2010 | JAMA
19567909 | The benefits of statins in people without established cardiovascular disease but with cardiovascular risk factors: meta-analysis of randomised controlled trials | 2009 | BMJ
19460803 | Use of non-invasive ventilation to wean critically ill adults off invasive ventilation: meta-analysis and systematic review | 2009 | BMJ
18495631 | Hormone replacement therapy and risk of venous thromboembolism in postmenopausal women: systematic review and meta-analysis | 2008 | BMJ
17923720 | Dietary antioxidants and primary prevention of age related macular degeneration: systematic review and meta-analysis | 2007 | BMJ
19200918 | Imaging strategies for low-back pain: systematic review and meta-analysis | 2009 | Lancet
18177773 | Adjuvant chemotherapy in oestrogen-receptor-poor breast cancer: patient-level meta-analysis of randomised trials | 2008 | Lancet
19724046 | Combined corticosteroid and antiviral treatment for Bell palsy: a systematic review and meta-analysis | 2009 | JAMA
16818928 | Meta-analysis: Cysticidal drugs for neurocysticercosis: albendazole and praziquantel | 2006 | Ann Intern Med
17310052 | Meta-analysis: anticoagulant prophylaxis to prevent symptomatic venous thromboembolism in hospitalized medical patients | 2007 | Ann Intern Med
19033591 | Inhaled corticosteroids in patients with stable chronic obstructive pulmonary disease: a systematic review and meta-analysis | 2008 | JAMA
19017592 | Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians | 2008 | Ann Intern Med
17237299 | Pharmacological and lifestyle interventions to prevent or delay type 2 diabetes in people with impaired glucose tolerance: systematic review and meta-analysis | 2007 | BMJ
17426275 | Corticosteroids for the prevention of atrial fibrillation after cardiac surgery: a randomized controlled trial | 2007 | JAMA
19141768 | Treatment of fibromyalgia syndrome with antidepressants: a meta-analysis | 2009 | JAMA
19661138 | Corticosteroids for pain relief in sore throat: systematic review and meta-analysis | 2009 | BMJ
16458764 | Self-monitoring of oral anticoagulation: a systematic review and meta-analysis | 2006 | Lancet
19303634 | Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials | 2009 | Lancet
19995812 | Neuraminidase inhibitors for preventing and treating influenza in healthy adults: systematic review and meta-analysis | 2009 | BMJ
18283206 | Meta-analysis: effectiveness of drugs for preventing contrast-induced nephropathy | 2008 | Ann Intern Med
19620144 | Systematic review: glucose control and cardiovascular disease in type 2 diabetes | 2009 | Ann Intern Med
19050195 | Clinical equivalence of generic and brand-name drugs used in cardiovascular disease: a systematic review and meta-analysis | 2008 | JAMA
18632672 | Interventions before consultations to help patients address their information needs by encouraging question asking: systematic review | 2008 | BMJ
16473126 | Obstetric outcomes after conservative treatment for intraepithelial or early invasive cervical lesions: systematic review and meta-analysis | 2006 | Lancet
16443611 | Effect of hepatitis B immunisation in newborn infants of mothers positive for hepatitis B surface antigen: systematic review and meta-analysis | 2006 | BMJ
20472172 | Time to treatment with intravenous alteplase and outcome in stroke: an updated pooled analysis of ECASS, ATLANTIS, NINDS, and EPITHET trials | 2010 | Lancet
17577006 | Meta-analysis: acupuncture for osteoarthritis of the knee | 2007 | Ann Intern Med
16380593 | Noninvasive ventilation in acute cardiogenic pulmonary edema: systematic review and meta-analysis | 2005 | JAMA
18390914 | Healing by primary closure versus open healing after surgery for pilonidal sinus: systematic review and meta-analysis | 2008 | BMJ
16679330 | Systematic review and meta-analysis of ethnic differences in risks of adverse reactions to drugs used in cardiovascular medicine | 2006 | BMJ
16389253 | Meta-analysis: protein and energy supplementation in older people | 2006 | Ann Intern Med
17517853 | Effect of rosiglitazone on the risk of myocardial infarction and death from cardiovascular causes | 2007 | N Engl J Med
18594042 | Early invasive vs conservative treatment strategies in women and men with unstable angina and non-ST-segment elevation myocardial infarction: a meta-analysis | 2008 | JAMA
19376798 | Four layer bandage compared with short stretch bandage for venous leg ulcers: systematic review and meta-analysis of randomised controlled trials with data from individual patients | 2009 | BMJ
16616558 | Effect of non-invasive positive pressure ventilation (NIPPV) on mortality in patients with acute cardiogenic pulmonary oedema: a meta-analysis | 2006 | Lancet
17438317 | Meta-analysis: chondroitin for osteoarthritis of the knee or hip | 2007 | Ann Intern Med
19666987 | Neuraminidase inhibitors for treatment and prophylaxis of influenza in children: systematic review and meta-analysis of randomised controlled trials | 2009 | BMJ
17606956 | Beta-blockers and progression of coronary atherosclerosis: pooled analysis of 4 intravascular ultrasonography trials | 2007 | Ann Intern Med
18321957 | Treatment of human brucellosis: systematic review and meta-analysis of randomised controlled trials | 2008 | BMJ
18299289 | Effects of statins in patients with chronic kidney disease: meta-analysis and meta-regression of randomised controlled trials | 2008 | BMJ
19493939 | A comparison of fluoroquinolones versus other antibiotics for treating enteric fever: meta-analysis | 2009 | BMJ
18480116 | Effects of different regimens to lower blood pressure on major cardiovascular events in older and younger adults: meta-analysis of randomised trials | 2008 | BMJ

## Excluded Studies

No studies were excluded.