# Appendix A Search Strategies

All searches were performed in MEDLINE (through the PubMed interface). The searches for systematic reviews with meta-analysis and cost-effectiveness analyses were performed on November 9, 2010; the search for value of information analyses was performed on July 16, 2010.

## Searches for systematic reviews with meta-analysis

(("meta-analysis"[Publication Type] OR "meta-analysis as topic"[MeSH Terms]) AND (new england journal of medicine[journal] OR lancet[journal] OR british medical journal[journal] OR annals of internal medicine[journal] OR journal of the american medical association[journal]) AND ("2005/11/11"[PDat] : "2010/11/08"[PDat])) NOT ("letter"[Publication Type] OR "editorial"[Publication Type] OR "comment"[Publication Type])

## Searches for cost-benefit analyses

("cost-benefit analysis"[MeSH Terms]) AND (new england journal of medicine[journal] OR lancet[journal] OR british medical journal[journal] OR annals of internal medicine[journal] OR journal of the american medical association[journal] OR medical decision making[journal] OR Pharmacoeconomics[journal] OR International Journal of Technology Assessment in Health Care[journal]) AND ("2005/11/11"[PDat] : "2010/11/08"[PDat])) NOT ("letter"[Publication Type] OR "editorial"[Publication Type] OR "comment"[Publication Type])

## Searches for value of information analyses

(value) AND ((perfect OR imperfect OR partial OR sample) AND information*)) OR "EVPI" OR "EVSI" OR "EVPPI" OR "perfect information" OR "value of clairvoyance" OR "value of information" OR "value-of-information"