# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CE: Cost-effectiveness
CEAC: Cost-effectiveness acceptability curves
CEAF: Cost-effectiveness acceptability frontier
EPC: Evidence-based Practice Center
EVPI: Expected value of perfect information
EVPPI: Expected value of partial perfect information
EVSI: Expected value of sample information
EVSI-P: Expected value of sample information for parameters
ICER: Incremental cost-effectiveness ratio
MIPD: Meta-analysis of individual patient data
NA: Not applicable
PCI: Percutaneous coronary intervention
QALY: Quality adjusted life year
RCT: Randomized controlled trial
VOI: Value of information