# Technical Expert Panel

Jodi Segal, M.D., M.P.H.

Johns Hopkins University School of Medicine

Baltimore, MD

Steven Goodman, M.D., Ph.D.

Johns Hopkins University School of Medicine

Baltimore, MD