# Results

## Step 1 Focused Literature Review

Our search identified 864 unique citations. Eight hundred and twenty-five (95.5%) of these were excluded from further consideration during title and abstract screening. The primary reasons for exclusion at this level were: did not have an objective to identify gaps/needs (n=619), did not use a systematic review (n=119), and did not include a description of methods/process (n=12). Of the 39 articles screened at full-text, 34 (87.2%) were excluded. The primary reasons for exclusion of full-text articles were: article did not use a systematic review (n=14), article did not include a description of methods/process for identifying research gaps/needs (n=10), and article did not have an objective to identify gaps/needs (n=5). We thus included five articles in the focused literature review.1–5 Figure 1 provides a summary of the searching and screening process.

Figure 1 Step 1: Focused literature review—Summary of search and review process

^1^MEDLINE^©^ was accessed via PubMed.

Figure 1 is a flow chart that outlines the search and review process we used during Step 1 (Focused Literature Review). It begins with the total number of citations retrieved from the literature search and ends with the number of studies that satisfied the inclusion criteria for the review. The electronic database searched was MEDLINE©, accessed via PubMed. This figure is described further in the results section under Step 1 - Focused Literature Review as follows: “Our search identified 864 unique citations. Eight hundred and twenty-five (95.5 percent) of these were excluded from further consideration during title and abstract screening. The primary reasons for exclusion at this level were: did not have an objective to identify gaps/needs (n=619), did not use a systematic review (n=119), and did not include a description of methods/process (n=12). Of the 39 articles screened at full-text, 34 (87.2%) were excluded. The primary reasons for exclusion of full-text articles were: article did not use a systematic review (n=14), article did not include a description of methods/process for identifying research gaps/needs (n=10), and article did not have an objective to identify gaps/needs (n=5). We thus included five articles in the focused literature review.1–5”

Table 1 describes the five included articles,1–5 published between 2001 and 2009. These addressed a variety of conditions—chronic noncancer pain,1 sexually transmitted infections (STIs) in teenagers,2 acute pain management in children and young people,2 infertility, 4 and chronic benign pain syndromes.5 One article was not specific to any particular clinical topic area.3

Table 1 Step 1: Focused literature review—Summary of included articles with methods/frameworks used

Author (Year)^Ref^ | Topic Area | Relevant Text From Article | Summary of Method/Framework Used
Chou (2009)1 | Chronic non-cancer pain | To assign an overall strength of evidence (good, fair, or poor), the number, quality, and size of the studies; consistency of results between studies; and directness of the evidence were considered.; - Consistent results from a number of higher-quality studies across a broad range of populations support a high degree of certainty that the results of the studies are true (the entire body of evidence would be considered “good-quality”).; - For a “fair-quality” body of evidence, results could be due to true effects or due to biases present across some or all of the studies.; - For a “poor-quality” body of evidence, any conclusion is uncertain due to serious methodological shortcomings, sparse data, or inconsistent results. | Research gaps were identified as the key questions that were addressed by only "poor-quality" evidence. [underlined: Organizing Principle(s)] - Key question.
Shepherd (2007)2 | - STIs in teenagers; - Acute pain management in children and young people (28 days - 19 years) | The included literature was read, assimilated, and mapped to the appropriate nodes of the care pathway. This process was performed by one researcher and checked by a second. Additional areas for intervention along the care pathway were identified during this assimilation process. Validation of this process was undertaken by an independent reviewer. The quality of the guidelines was appraised narratively using the AGREE appraisal tool. Analysis of the populated care pathway and narrative map (the framework based on the care pathway) facilitated the identification of gaps in research evidence and policy literature. The gaps were identified by (i) analyzing those areas of the care pathway lacking appropriate guidelines/guidance or evaluation research, (ii) noting gaps cited within existing guidelines/guidance or evaluation research, and (iii) identifying poor-quality and out-of-date studies and guidelines/guidance. | A care pathway was developed for each condition. Gaps were identified using the following three criteria to assess areas within the care pathway:; - analyzing those areas of the care pathway lacking appropriate guidelines/guidance or evaluation research,; - noting gaps cited within existing guidelines/guidance or evaluation research, and; - identifying poor-quality and out-of-date studies and guidelines/guidance.; [underlined: Organizing principle(s)] - C are pathway.
Clarke (2007)3 | Not specific | One author read each record and categorized it on the basis of whether a recommendation was made as to the need for more research and, if so, whether suggestions were made regarding the specific types of intervention, participant, or outcome measures that should be assessed or included in future research. In addition, suggestions for a new, expanded, or updated systematic review were noted. Another author read each record to identify whether it mentioned a specific ongoing or planned study. The third author read each record, checked the assigned codes, and made the final decision on the coding of each record. Subsequently, details were obtained on the content of the “ongoing studies” sections. The number of studies listed for each review was counted and cross-checked by two of the authors. | Uses the Implications for Research sections of all Cochrane reviews from one issue of the Cochrane Library (various topics). Reviews were categorized by whether a recommendation was made as to the need for more research and, if so, whether suggestions were made regarding the types of intervention, participant, or outcome measures that should be included in future research. In addition, suggestions for a new, expanded, or updated systematic review were noted. It was also noted whether reviews mentioned a specific ongoing or planned study. Subsequently, details were obtained on the content of the “ongoing studies” sections. [underlined: Organizing principle(s)] - By types of intervention, types of participant, and types of outcome measures.
Johnson (2003)4 | Infertility | The following information as collected from each review: the number of trials available for meta- analysis, the total number of trial participants available for meta-analysis and whether there was an answer to the primary clinical question-into which category from (A) to (C), below, the review fell: (A) Where there is evidence of effectiveness or harm from a metaanalysis of trial data. The term “relative effectiveness” was used when two interventions were compared and the term “effectiveness” was used when the treatment was compared with either placebo or no treatment. (B) Where there is insufficient evidence of effectiveness and the review authors have called for further research. (C) Where there is insufficient evidence of effectiveness and the review authors have not called for further research. | Uses Cochrane reviews to identify areas of insufficient evidence. Gaps were identified if one of the following two criteria were fulfilled (based on review authors' definition of the sufficiency of evidence):; - Where there is insufficient evidence of effectiveness and the review authors have called for further research.; - Where there is insufficient evidence of effectiveness and the review authors have not called for further research.; [underlined: Organizing principle(s)] - Topic area.
de Vet (2001)5 | Chronic benign pain syndromes | The methodologic quality of the relevant reviews was assessed according to the method developed by Assendelft et al. on a 0–100 point scale. If reviews of reasonable (60–79 points) to good quality (≥80 points) were found, their conclusions (effective, not effective, inconclusive) were adopted. If only reviews of poor or moderate quality were found, a new systematic review was recommended. If no recent reviews of a specific topic were found, a search was made for randomized controlled trials (RCTs), using the strategy recommended by the Cochrane Collaboration. If there were more than five RCTs in the computerized databases mentioned above, a systematic review was recommended. If there were five RCTs or less, the following data were extracted from the abstract: the design (parallel or a crossover study), the sample size, whether the trial was really randomized, whether it was blinded, which interventions were compared, and the conclusions. If the conclusions were inconsistent, a new RCT was recommended. If the results appeared to be consistent, it was advised that the evidence of (in)effectiveness should be studied in detail in order to decide on the level of evidence. When the evidence from a small number of studies is convincing, it should be incorporated in a clinical guideline. A decision tree was used for this purpose for each intervention-syndrome combination (topic). This resulted in a list of topics for the nine chronic benign pain syndromes for which systematic reviews were recommended and a list of topics for which new RCTs were needed. | A decision tree was generated to decide about the need for a new systematic review or the need for a new RCT for each topic. Lists of research gaps/needs were identified as areas of insufficient or inconsistent evidence. These lists were then prioritized. [underlined: Organizing principle(s)] - Decision tree

Abbreviations: AGREE=appraisal of guidelines research and evaluation, RCT=randomized controlled trial, STI=sexually transmitted infection.

Chou et al. (2009) organized research gaps by key question.1 Research gaps were identified as key questions for which there was “poor quality” body of evidence. The authors defined evidence to be of poor quality if any conclusion was uncertain due to serious methodological shortcomings, sparse data, or inconsistent results.1

Clarke et al. (2007) used the “Implications for Research” sections of all Cochrane reviews from a single issue (Issue 4, 2005) of The Cochrane Library to identify research gaps.3 Research gaps were identified based on whether a recommendation was made as to the need for more research, and if so, whether review authors made suggestions regarding the specific types of intervention, participant, or outcome measures that should be assessed or included in that research.3 Johnson et al. (2003) also used Cochrane reviews to identify research gaps/needs.4 They organized research gaps/needs by topic area and identified research gaps/needs as topics where there was insufficient (as defined by the review authors) evidence, whether or not review authors called for further research.4

Shepherd et al. (2007) developed care pathways for the management of STIs in teenagers and for the acute pain management in children and young people (28 days to 19 years of age).2 Research gaps/needs were identified within the care pathway as areas lacking appropriate guidelines/guidance or evaluation research; areas with gaps cited within existing guidelines/guidance or evaluation research; or areas with poor-quality and out of date studies and guidelines/guidance.2 De Vet et al. (2001) generated a detailed decision tree to decide about the need for a new systematic review or the need for a new randomized controlled trial (RCT) for each topic.5 Research gaps/needs were identified as areas of insufficient or inconsistent evidence. Two lists of research gaps/needs were generated (one for systematic reviews and one for RCTs) and then prioritized.5

Table 1 also provides a summary of the method/framework used by the authors of the articles for the identification of research gaps/needs. The organizing principles included key question;1 a care pathway;2 types of participants, interventions, and outcome measures;3 topic area;4 and a decision tree.5 The literature described in varying detail how research gaps were defined or identified. Specifics on what was described are also provided in Table 1.

## Step 2 Review of Current Practices of Evidence-based Practice Centers (EPCs)

### Audit of Evidence Reports From EPCs

As of April 20, 2010 there were fourteen current EPCs (as listed on the AHRQ website). These EPCs had produced a total of twenty-nine eligible evidence reports (mean 2.4 per EPC, median 1.5 per EPC, range 0 to 7). These included twenty-six clinical reports and three health care services reports. Two EPCs (ECRI EPC and University of Connecticut EPC) had not produced any evidence report after 2008 that met our inclusion criteria.

The twelve evidence reports randomly selected after stratification by EPC (one from each remaining EPC) are listed in Table 2.^6–17^ These included eleven clinical reports6–9,11–17 and one health care services report.10 The topic areas covered included: obstetric and gynecological conditions (three reports);7,11,12 cancer and blood disorders (two reports);6,8 complementary and alternative care (one report);9 information technology (one report);10 dietary supplements (one report);13 metabolic, nutritional, and endocrine conditions (one report);14 mental health conditions and substance abuse (one report);15 heart and vascular diseases (one report);16 and kidney/urological conditions (one report).17

Table 2 Step 2: Review of current practices of evidence-based practice centers (EPCs)—Summary of randomly selected evidence reports

Sr no. | EPC Name | Type of Report | Topic Area | Title of Evidence Report, Ref | Year of Release
1 | Blue Cross and Blue Shield Association | Clinical | Cancer & blood disorders | HER2 testing to manage patients with breast cancer or other solid tumors6 | 2008
2 | Duke University EPC | Clinical | Obstetric and gynecologic conditions | Effectiveness of assisted reproductive technology7 | 2008
3 | Johns Hopkins University EPC | Clinical | Cancer & blood disorders | Impact of gene expression profiling tests on breast cancer outcomes8 | 2008
4 | McMaster University EPC | Clinical | Complementary & alternative care | Complementary and alternative medicine in back pain utilization report9 | 2009
5 | Oregon EPC | Health Care Services | Information technology | Barriers and drivers of health information technology use for the elderly, chronically ill, and underserved10 | 2008
6 | RTI International - UNC EPC | Clinical | Obstetric and gynecologic conditions | Outcomes of maternal weight gain11 | 2008
7 | Southern California/ RAND EPC | Clinical | Obstetric and gynecologic conditions | Bariatric surgery in women of reproductive age: Special concerns for pregnancy12 | 2008
8 | Tufts University EPC | Clinical | Dietary supplements | Vitamin D and calcium: A systematic review of health outcomes13 | 2009
9 | University of Alberta EPC | Clinical | Metabolic, nutritional, and endocrine conditions | Diabetes education for children with type 1 diabetes mellitus and their families14 | 2008
10 | University of Minnesota EPC | Clinical | Mental health conditions and substance abuse | Integration of mental health/substance abuse and primary care15 | 2008
11 | University of Ottawa EPC | Clinical | Heart and vascular diseases | Diagnosis and treatment of erectile dysfunction16 | 2009
12 | Vanderbilt University EPC | Clinical | Kidney/ urological conditions | Treatment of overactive bladder in women17 | 2009

Abbreviations: EPC=evidence-based practice center, HER2=human epidermal growth factor receptor 2, RAND=Research and Development, RTI=Research Triangle Institute, UNC=University of North Carolina

Table 3 presents a summary of our audit of these twelve evidence reports. None of the reports defined what was meant by research gaps or research needs. Only one (8.3%) report used an explicit framework/set of organizing principles for the identification of research gaps/needs. This involved the description of the gap using the population, intervention, comparison, and outcomes (PICO) framework.

Table 3 Step 2: Review of current practices of evidence-based practice centers (EPCs)—Audit of randomly selected evidence reports

Sr No | EPC Name (Ref no.) | Were the Terms “Research Gaps” or “Research Needs” Defined? | Was There a Description of how Research Gaps/ Needs Were Identified? | Was There an Explicit Framework (e.g., PICO) for Identifying Research Gaps/Needs? | Were Future Research Gaps/Needs Provided, and Where Were They Found? | How Were Research Gaps/Needs Presented?
1 | Blue Cross and Blue Shield Association6 | No | No | No | Yes, discussion section | Bullet-point list
2 | Duke University EPC7 | No | No | No | Yes, separate chapter | Bullet-point list
3 | Johns Hopkins University EPC8 | No | No | No | Yes, discussion section | Numbered list
4 | McMaster University EPC9 | No | No | Yes, PICO framework | Yes, discussion section | Numbered list
5 | Oregon 10 EPC | No | No | No | Yes, separate chapter | Embedded in text
6 | RTI International - UNC EPC11 | No | No | No | Yes, discussion section | Bullet-point list
7 | Southern California/ RAND EPC12 | No | No | No | Yes, discussion section | Embedded in text
8 | Tufts University EPC^*,13^ | No | Yes | Yes, PICO framework | Yes, separate chapter | Table
9 | University of Alberta EPC14 | No | No | No | Yes, discussion section | Bullet-point list
10 | University of Minnesota EPC15 | No | No | No | Yes, discussion section | Table
11 | University of Ottawa EPC16 | No | No | No | Yes, discussion section | Embedded in text
12 | Vanderbilt University EPC17 | No | No | No | Yes, discussion section | Bullet-point list

Abbreviations: EPC=evidence-based practice center, PICO=population, intervention, comparison, and outcomes=RAND=Research and Development, RTI=Research Triangle Institute, UNC=University of North Carolina

* This EPC’s report was initially classified as not having provided research gaps/needs. However, after clarification from the EPC during the verification of the audit, this report was subsequently classified as having provided research gaps/needs in a table in a separate chapter using the PICO framework.

All reports provided future research gaps/needs (see Table 3). Of these, nine (75%)6,8,9,11,12,14–17 reports provided future research gaps/needs in the discussion section while three (25%)7,10,13 provided them in a separate chapter. Five (41.7%)6,7,11,14,17 separated out research gaps/needs using bulleted lists; three (25.0%)10,12,16 embedded research gaps/needs in text; two (16.7%)8,9 separated research gaps/needs using numbered lists; and two (16.7%)13,15 presented research gaps/needs in tables.

### Verification of Abstracted Information

We contacted the twelve EPCs which produced the evidence reports and sought any corrections and clarifications on what we had abstracted from those reports. We obtained feedback from each of these EPCs.

A summary of the responses from the EPCs is available in Appendix C. Although we had initially classified only one report9 as using an explicit framework (PICO), we reclassified a second report13 as using the PICO framework after receiving feedback from the EPC. Two additional EPCs reported that they had subsequently adopted the PICO framework to characterize research gaps. Thus, four of twelve (33.3%) EPCs currently use the PICO framework to characterize research gaps.

Several of the EPCs provided further details about how they define or identify research gaps, including areas with no studies identified; studies with methodological issues contributing to low quality; studies with insufficient information on important subgroups or outcomes; etc. Details are provided in Appendix C.

## Step 3 Review of Current Practices of Organizations Involved With Evidence Synthesis

Sixty-four organizations met our inclusion criteria and are listed in Appendix D. These included seven each from Australia, the UK, and the US, six from Spain, five from Canada, and thirty-two from other countries. As of April 27, 2010, fifteen organizations were involved with the conduct of systematic reviews, fifty-five with HTAs, and four with CEAs. Seven organizations were involved with the conduct of more than one of these activities.

We obtained responses from thirty-seven organizations (response rate = 57.8%), including seven from Australia, five from Canada, five from the UK, four from the United States, two from Spain, and fourteen from other countries. Among these thirty-seven organizations, fifteen (40.5%) reported having a formal process to identify research gaps/needs (see Table 4). However, we determined that only four of these fifteen organizations had a formal process for the identification of primary research gaps/needs. The other eleven organizations reported processes that did not meet our definition of a formal process (n=9) or were formal processes for the identification of needs for systematic reviews and HTAs (n=1) or guidelines (n=1). We thus determined that four (10.8%) of the thirty-seven organizations had a formal process for the identification of primary research gaps/needs (see Appendix E and Table 4).

Table 4 Step 3: Review of current practices of organizations involved with evidence synthesis—Summary of organizations which reported having formal processes

Sr No | Country | Organization Name | Our Determination of Nature of Reported Process | Organizing Principle
1 | Australia | Caring for Australasians with Renal Impairment | Process is not formal | -
2 | Australia | Joanna Briggs Institute | Process is not formal | -
3 | Canada | Canadian Agency for Drugs and Technologies in Health | Process is not formal | -
4 | Canada | Program in Evidence-based Care | Process is formal, identifies gaps/needs for:; - Guidelines | None identified
5 | Finland | Finnish Office for Health Technology Assessment | Process is not formal | -
6 | Italy | HTA Unit in A. Gemelli Teaching Hospital | Process is not formal | -
7 | New Zealand | Health Services Assessment Collaboration | Process is formal, identifies gaps/needs for:; - Systematic reviews; - HTAs | PICO
8 | Spain | Catalan Agency for Health Information, Assessment and Quality | Process is formal, identifies gaps/needs for:; - Primary research | None identified
9 | Sweden | The Swedish Council on Technology Assessment in Health Care | Process is not formal | -
10 | The Netherlands | The Medical and Health Research Council of The Netherlands | Process is not formal | -
11 | UK | National Institute for Health and Clinical Excellence | Process is formal, identifies gaps/needs for:; - Systematic reviews; - Primary research | PICO
12 | UK | NIHR Coordinating Centre for Health Technology Assessment | Process is not formal | -
13 | UK | Scottish Intercollegiate Guidelines Network | Process is formal, identifies gaps/needs for:; - Primary research | Key question
14 | US | American Academy of Otolaryngology - Head and Neck Surgery Foundation | Process is not formal | -
15 | US | National Kidney Foundation | Process is formal, identifies gaps/needs for:; - Primary research | PICOD

Abbreviations: HTA=health technology assessment, NIHR=National Institute for Health Research, PICO=population, intervention, comparison, and outcomes, PICOD=population, intervention, comparison, outcomes, and time points, UK=United Kingdom, US=United States

Two organizations reported the use of the PICO framework for identifying research gaps/needs. These included the National Kidney Foundation (NKF) in the US and the National Institute for Health and Clinical Excellence (NICE) in the UK. NKF reported the use of the PICOD framework which, in addition to the elements in the PICO framework, includes the element of time points for outcomes measurement (D).

The Scottish International Guidelines Network (SIGN) used key questions from guidelines as the organizing framework while identifying research gaps/needs. It was reported that if a question is seen as particularly important and there is no evidence, or only such poor evidence that the guideline development group does not feel able to make a recommendation, then a recommendation for further research is made.

## Step 4 Development of Framework

We did not identify one framework that we felt captured all elements needed to determine research gaps. Variations of the PICO framework were used by some EPCs and other agencies to characterize research gaps. We thus include this as part of our proposed framework. However, we felt it was also important to classify the reason(s) for the gap to help to determine how to address the gap. Therefore, based on information from steps 1 through 3, we propose a framework that includes (i) the identification and classification of the reason(s) why the research gap exists and (ii) the characterization of the research gap using the PICOS (population, intervention, comparison, outcomes, and setting) elements.

We propose that the most important reason(s) for the existence of the research gap be chosen. The reason(s) selected should be those that most preclude conclusions from being made. Put another way, investigative teams should consider what would be needed to allow for conclusions to be made. The proposed classification of the reasons for research gaps includes:

- Insufficient or imprecise information
- Biased information
- Inconsistency or unknown consistency
- Not the right information.

We recognize that there is an overlap with identifying gaps and the tasks completed during the grading of the evidence. To facilitate leveraging the work being completed during the grading, we have included with each description the corresponding domain/element in three common evidence grading systems: the EPC Strength of Evidence (SOE)system;18 the Grading of Recommendations Assessment, Development and Evaluation (GRADE) system;19 and the United States Preventive Services Task Force (USPSTF) system.20

### A Insufficient or Imprecise Information

Insufficient information can arise if no studies are identified, if a limited number of studies are identified, or if the sample sizes in the available studies are too small to allow conclusions about the question of interest. If the information available in identified studies is insufficient to allow a conclusion or if the estimate of the effect (usually achieved from a meta-analysis) is imprecise there is a research gap. Precision is the degree of certainty surrounding the effect estimate.18 An imprecise estimate has been defined as one for which the confidence interval is wide enough to include both superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that precludes a conclusion.18 Imprecision in the meta-analytic effect estimate may result as a consequence of a small number of studies in the meta-analysis or small sample sizes in included studies (leading to imprecision in individual study effect sizes). Where meta-analysis is not conducted, imprecision of the individual studies should be evaluated.

Correspondence to grading systems:

- EPC SOE: Precision is a required domain.
- GRADE: The GRADE Working Group advises decreasing the grade of the quality of the evidence if the data are “imprecise or sparse”.
- USPSTF: The following questions are considered while grading the evidence:
  ○ “How many studies have been conducted that address the key question(s)?”
  ○ “How large are the studies? (i.e., what is the precision of the evidence?)”

### B Biased Information

Various criteria exist for assessing the risk of bias of studies of different study designs. The aggregate risk of bias is contingent upon the risk of bias of the individual studies.18 In addition to considering methodological limitations of studies, the appropriateness of the study design should also be considered. An example of a research gap that arises due to methodological limitations of existing studies is: There is a need for more randomized controlled trials with outcome assessor blinding to compare the effects of various newer oral diabetes agents in women with gestational diabetes.

Correspondence to grading systems:

- EPC SOE: Risk of bias is a required domain. It incorporates the elements of study design and aggregate quality of the studies under consideration.
- GRADE: Study quality and study design are key elements.
- USPSTF: The following questions are considered while grading the evidence:
  ○ “To what extent are the existing studies of high quality? (i.e., what is the internal validity?)”
  ○ “Do the studies have the appropriate research design to answer the key question(s)?”

### C Inconsistency or Unknown Consistency

In the EPC SOE system, consistency is defined as the degree to which reported effect sizes from included studies appear to go in the same direction.18 The two elements are whether effect sizes have the same sign (same side of “no effect”) and whether the range of effect sizes is narrow.18 According to the GRADE system, consistency refers to the similarity of estimates of effect across studies, incorporating direction of effect, size of differences in effect, and the significance of the differences in effect size.19 However, it should be kept in mind that a statistically significant effect size in one study and an effect size whose confidence interval overlaps null in another study do not necessarily constitute inconsistent results. If there is only one available study, even if considered large sample size, the consistency of results is unknown.18

Correspondence to grading systems:

- EPC SOE: Consistency is a required domain.
- GRADE: Consistency is a key element.
- USPSTF: The following question is considered while grading the evidence:
  ○ “How consistent are the results of the studies?”

### D Not the Right Information

There are a number of reasons why identified studies might not provide the right information. First, results from studies might not be applicable to the population and/or setting of interest. Second, the optimal or most important outcomes might not be assessed. For example, studies might only include surrogate or intermediate outcomes. Third, the study duration might be too short and patients might not be followed up for long enough duration to adequately assess some outcomes which might be most important.

Correspondence to grading systems:

- EPC SOE: Applicability is as an 'other pertinent issue'. Directness is a required domain. It also incorporates the element of surrogate versus clinical outcomes.
- GRADE: Directness is a key element, incorporating the elements of applicability and surrogate versus clinical outcomes.
- USPSTF: The following question is considered while grading the evidence:
  ○ “To what extent are the results of the studies generalizable to the general U.S. primary care population and situation? (i.e., what is the external validity?)”

### Characterization of Research Gaps

To further characterize the research gaps we propose using the PICOS framework using the population (P), intervention (I), comparison (C), outcomes (O), and setting (S). Those elements which are inadequately addressed in the evidence base should be characterized. The other relevant elements will be apparent from the key question from which the research is derived. It follows that for research questions that do not relate to a specific key question, all available elements of the research gap should be characterized.

#### Population (P)

Information here should be as specific as possible as to the age, sex, race/ethnicity, clinical stage, etc. of the population that is not adequately represented in the evidence base. However, it should be recognized that research gaps often do not relate to any specific population but refer to the general population.

Examples of populations include: women with gestational diabetes, adults on anti-depressive medication, and African Americans with Helicobacter pylori infection.

#### Intervention (I)

The specific name of the intervention that is inadequately included in the evidence base (generic names of drugs and devices are preferred), the duration of the intervention, its dose, its frequency, who will administer it, etc. should be specified. As with the population, it may not always be appropriate to specify great detail about the intervention.

Examples of interventions include: metformin, selective serotonin reuptake inhibitors (SSRIs), any oral antihistaminic drug, and total thyroidectomy.

#### Comparison (C)

The same relevant details about the comparative intervention should be specified as for the intervention of interest – name of comparative intervention, its duration, its dose, its frequency, who will administer it, etc. If the comparison is “any other intervention,” this should be indicated. Similarly, if the comparison is “no intervention” or placebo, it should be specified as such. It should also be recognized that there may be instances where there is no specific comparison of interest.

Examples of comparisons include: any insulin, any non-steroidal anti-inflammatory drug (NSAID), hemithyroidectomy, and placebo.

#### Outcomes (O)

It may be appropriate to organize outcomes by type of outcomes or to only list the types of outcomes (e.g., maternal outcomes and fetal outcomes, liver outcomes, and renal outcomes). If appropriate, the timing of outcome assessments that are missing should be specified (e.g., body mass index [BMI] at 12 months, 5-year survival rate). If there are no specific outcomes of interest, this should be indicated.

Examples of outcomes include: neonatal hypoglycemia, neonatal intensive care unit (NICU) admissions; liver outcomes (alanine transaminase [ALT], aspartate transaminase [AST]); and renal outcomes (proteinuria, serum creatinine).

#### Setting (S)

Where appropriate, members should specify the relevant settings for research gaps.

Examples of settings include: at home, in the hospital, in the outpatient setting, in the United States.

### Special Considerations

In addition to characterizing research gaps that relate to treatment interventions, the PICOS framework can be used to characterize gaps that relate to diagnostic tests, clinical assessments, and screening tests. These are described below.

Research gaps relating to the accuracy of diagnostic tests can be fit into the PICOS framework by considering the diagnostic test under investigation as the intervention (I) and the gold or reference standard test as the comparison (C). Relevant outcomes (O) in this case could include sensitivity, specificity, and other metrics of test performance.

Research gaps relating to the benefit of one form (or frequency) of clinical assessment (e.g., monitoring) versus another can be fit into the PICOS framework by considering these clinical assessments as intervention (I) and comparison (C). The comparison in this case could include a standard form (or frequency) of clinical assessment or no clinical assessment. Relevant outcomes (O) could include clinical outcomes to assess the benefit of the clinical assessment(s).

Research gaps relating to screening tests can be fit into the PICOS framework by considering these tests as intervention (I) and comparison (C). Relevant outcomes (O) could include clinical outcomes to assess the benefit of the screening test(s).

Research gaps which are difficult to characterize into the PICOS framework should be abstracted in free text form. Interventions could potentially include a range of treatment options, order of treatment options, individualization of treatments, etc. These are often gaps for which it is difficult to identify a clear intervention or comparison of interest. Examples of research questions derived from such research gaps are: “What are the optimal glucose thresholds for medication use in women with gestational diabetes?”; “In what order should patients with cystic fibrosis perform their airway clearance therapies?” and “How should physicians choose an airway clearance therapy for a given patient with cystic fibrosis?”

### Worksheet

Using the above described framework, we designed a worksheet to facilitate the identification and organization of research gaps during evidence reviews sponsored by AHRQ (see Table 5). Our aim was to design a simple, user-friendly worksheet to help investigators record research gaps. We envision that investigators would fill out this worksheet soon after the data synthesis phase, while in the process of writing the results section of the evidence report. Having just completed reviewing the evidence in detail, we believe that this is the ideal time for investigators to comprehensively and accurately identify individual research gaps. See Appendixes E and F for the research gaps characterization worksheet and instructions for its completion, respectively.

Table 5 Step 4: Development of framework—Research gaps abstraction worksheet

The use of a worksheet may be beneficial in two main ways. First, it facilitates the use of a systematic process in identifying and recording research gaps during systematic reviews. This would also facilitate the discussion about research gaps between team members who might have written the results for different key questions. Second, the worksheet would enable investigative teams to write the future research section of an evidence report in a more organized and systematic manner. A proposed format for presenting research gaps in evidence reports is provided in the discussion section of this report.

## Step 5 Pilot Test of Framework

We pilot tested our framework on two randomly selected evidence reports not produced by our EPC.17,21 The average time taken to abstract research gaps was 3.5 hours per evidence report. On average, there were 14.75 research gaps identified per evidence report. On average, there were 2 (13.6%) research gaps per evidence report which could not be characterized using the PICOS framework. These research gaps did not relate to a specific intervention or comparison, but instead related to prevalence, incidence, and the effect of certain factors on prevalence and incidence. These research gaps were thus abstracted in free text form.

### Challenges To Use of Framework

We encountered a few challenges when pilot testing the framework. First, the average time taken to pilot test the framework was 3.5 hours per evidence report. This task was challenging predominantly because we were not involved with the conduct of the evidence reviews or the writing of their results. Completing the task often necessitated reading the background and methods of the report including details about the key questions themselves. It would likely be more efficient if this task is completed by the same team that completed the systematic review.

Second, only one of the two evidence reports that we used to pilot test our framework included a “strength of evidence” (SOE) table for each question of interest. If this table is adopted by investigative teams, they can leverage work that would already have been done in the completion of the table to identify research. According to this AHRQ-recommended evidence grading system, the overall strength of the evidence is graded as “high,” “moderate,” “low,” and “insufficient,”18 If the overall evidence is graded as “moderate,” “low,” or “insufficient” it is subjectively implied that further research at least may change our confidence in the estimate or may change the estimate itself.18 Research gaps can thereby be identified as topics or areas for which further research may change our conclusions (i.e., those graded as “moderate,” “low,” or “insufficient” strength of evidence using the AHRQ-recommended evidence grading system).

Third, the two research team members who carried out the pilot test often chose two different reasons for gaps when only one study was identified. These reasons were: A. insufficient information and C. unknown consistency. It was not decided beforehand what reason for gap would be selected if such gaps were identified.

Fourth, the two research team members also abstracted a different number of gaps because of differences in the specificity of the research gaps. It was not decided beforehand whether gaps should be abstracted at the key question level or at the level of specific comparisons (subquestions) within key questions. This was particularly an issue whenever no studies were identified for key questions with more than one specific comparison.

Similarly, when comparing the results of our pilot test with the future research sections of the evidence reports, the research gaps we identified were more specific. This arose because we identified each intervention and comparison as a separate research gap, while the authors of the evidence report tended to group together groups of interventions and comparisons. For example, two of our research gaps were related to the use of decision aids and physician reminders to improve the appropriate use of colorectal cancer screening. However, in the future research section of the evidence report, the authors were more general and suggested the development and testing of “promising interventions that need more research especially integrated with other practice systems and especially in combinations”.21

Fifth, as described above, some research gaps could not be abstracted using the framework and needed to be abstracted in free text form.

## Step 6 Refinement and Finalization of Framework

Changes to the framework and the worksheet at this stage only involved minor formatting and clarification of instructions.