# References

1 Chou R, Ballantyne JC, Fanciullo GJ, et al. (2009). Research gaps on use of opioids for chronic noncancer pain: findings from a review of the evidence for an American Pain Society and American Academy of Pain Medicine clinical practice guideline. J Pain.
2 Shepherd J, Briggs J, Payne L, et al. (2007). Setting the future policy agenda for health technology assessment: a specialty mapping approach. Int J Technol Assess Health Care.
3 Clarke L, Clarke M, Clarke T. (2007). How useful are Cochrane reviews in identifying research needs?. J Health Serv Res Policy.
4 Johnson NP, Proctor M, Farquhar CM. (2003). Gaps in the evidence for fertility treatment-an analysis of the Cochrane Menstrual Disorders and Subfertility Group database. Hum Reprod.
5 de Vet HC, Kroese ME, Scholten RJ, et al. (2001). A method for research programming in the field of evidence-based medicine. Int J Technol Assess Health Care.
6 Seidenfeld J, Samsom DJ, Rothenberg BM, et al. (2008). HER2 testing to manage patients with breast cancer or other solid tumors. Evid Rep Technol Assess (Full Rep).
7 Myers ER, McCrory DC, Mills AA, et al. (2008). Effectiveness of assisted reproductive technology (ART). Evid Rep Technol Assess (Full Rep).
8 Marchionni L, Wilson RF, Marinopoulos SS, et al. (2007). Impact of gene expression profiling tests on breast cancer outcomes. Evid Rep Technol Assess (Full Rep).
9 (2009). Complementary and alternative medicine in back pain utilization report. Evid Rep Technol Assess (Full Rep).
10 Jimison H, Gorman P, Woods S, et al. (2008). Barriers and drivers of health information technology use for the elderly, chronically ill, and underserved. Evid Rep Technol Assess (Full Rep).
11 Viswanathan M, Siega-Riz AM, Moos MK, et al. (2008). Outcomes of maternal weight gain. Evid Rep Technol Assess (Full Rep).
12 Shekelle PG, Newberry S, Maglione M, et al. (2008). Bariatric surgery in women of reproductive age: special concerns for pregnancy. Evid Rep Technol Assess (Full Rep).
13 Chung M, Balk EM, Brendel M, et al. (2009). Vitamin D and calcium: a systematic review of health outcomes. Evid Rep Technol Assess (Full Rep).
14 Couch R, Jetha M, Dryden DM, et al. (2008). Diabetes education for children with type 1 diabetes mellitus and their families. Evid Rep Technol Assess (Full Rep).
15 Butler M, Kane RL, McAlpine D, et al. (2008). Integration of mental health/substance abuse and primary care. Evid Rep Technol Assess (Full Rep).
16 Tsertsvadze A, Fink HA, Yazdi F, et al. (2009). Oral phosphodiesterase-5 inhibitors and hormonal treatments for erectile dysfunction: a systematic review and meta-analysis. Ann Intern Med.
17 Hartmann KE, McPheeters ML, Biller DH, et al. (2009). Treatment of overactive bladder in women. Evid Rep Technol Assess (Full Rep).
18 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol.
19 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. BMJ.
20 Sawaya GF, Guirguis-Blake J, LeFevre M, et al. (2007). Update on the methods of the U.S. Preventive Services Task Force: estimating certainty and magnitude of net benefit. Ann Intern Med.
21 Holden DJ, Harris R, Porterfield DS, et al. (2010). Enhancing the use and quality of colorectal cancer screening. Evid Rep Technol Assess (Full Rep).