# Peer Reviewers

Paula Adam, Ph.D.

Catalan Agency for Health Information, Assessment and Quality

Barcelona, Spain

Kalipso Chalkidou, M.D., Ph.D.

National Institute for Health and Clinical Excellence

London, UK

Roger Chou, M.D.

Oregon Evidence-based Practice Center

Portland, OR

Christa Harstall, M.H.S.A.

Institute of Health Economics

Edmonton, AB, Canada

Melissa McPheeters, Ph.D., M.P.H.

Vanderbilt Evidence-based Practice Center

Nashville, TN

Joan Pons, M.D., Ph.D.

Catalan Agency for Health Information, Assessment and Quality

Barcelona, Spain

Barbara Rothenberg, Ph.D.

BlueCross BlueShield Association Technology Evaluation Center Evidence-based Practice Center

Chicago, IL

P. Lina Santaguida, Ph.D.

McMaster University Evidence-based Practice Center

Hamilton, ON, Canada

Meera Viswanathan, Ph.D.

RTI-UNC Evidence-based Practice Center

Durham, NC