# Methods

We used multiple resources and sought different perspectives to develop a framework for the identification of research gaps. We carried out six steps. We first attempted to identify, enumerate and describe frameworks that have been used (steps 1 to 3). We then developed, tested and refined a framework (steps 4 to 6). The six steps are:

1. Focused literature review
2. Review of current practices of evidence-based practice centers (EPCs)
3. Review of current practices of organizations involved with evidence synthesis
4. Development of framework
5. Pilot test of framework
6. Refinement and finalization of framework.

## Step 1 Focused Literature Review

We sought English-language articles that described the identification of research gaps, research needs, or evidence gaps from systematic reviews or related processes such as health technology assessments (HTAs). We completed a search of MEDLINE^©^ via PubMed (April 22, 2010). We analyzed the terms used in eligible articles identified during preliminary searching to develop a search strategy. We combined controlled vocabulary terms and text words for systematic review, meta-analysis, evidence-based medicine, research needs, and research gaps to create the following search strategy:

((review literature as topic[mh] OR meta-analysis as topic[mh] OR evidence-based medicine[mh] OR systematic reviews[tiab] OR systematic review[tiab] OR technology assessment[tiab] OR technology assessments[tiab] OR meta-analysis[tiab] OR meta-analyses[tiab]) AND (research needs[tiab] OR gaps[tiab] OR research priorities[tiab])).

All search results were imported into a database maintained in reference management software (ProCite™, Thomson Reuters, New York, NY). A custom work form was used to track the searching and screening processes. All citations were screened for eligibility at the title and abstract level by one reviewer. Citations deemed eligible or of unclear eligibility were reviewed by a second reviewer. We obtained full-text articles of citations confirmed as eligible or of unclear eligibility. These full-text articles were then independently screened by two reviewers. Disagreements concerning eligibility were resolved by consensus or by a third reviewer. We excluded citations from further consideration if they:

- Were not in English;
- Did not have an objective to identify research gaps/needs;
- Did not use a systematic review or similar process to identify research gaps/needs;
- Did not include a description of methods or process for identifying research gaps/needs; or
- Were otherwise eligible but used guidelines as basis for identification of research gaps/needs.

We scanned the reference lists of included articles. From each included article we abstracted the topic area and the method of identifying research gaps/needs that was described in the text or figures. We also abstracted the organizing principle(s) that was (were) used to identify research gaps/needs.

## Step 2 Review of Current Practices of Evidence-based Practice Centers (EPCs)

### Audit of Evidence Reports From EPCs

We searched the AHRQ website (http://www.ahrq.gov/) for evidence reports that satisfied the following criteria (as of April 12, 2010):

- Published in 2008 or later;
- Classified as “Clinical” or “Health Care Services” (we did not consider “Technical” reports); and
- Produced by an EPC that is part of AHRQ’s EPC program between 2007 and 2012.

We randomly selected one report if there was more than one report that satisfied the above criteria from the same EPC. One team member abstracted the following data from each of the evidence reports using a form designed in Excel (Microsoft™, Redmond, WA) (see Appendix B for data abstraction form):

- Whether or not the terms research gaps/needs were defined;
- Whether or not there was a description of how research gaps/needs were identified;
- Whether or not there was an explicit framework/set of organizing principles used for the identification of research gaps/needs;
- Whether or not research gaps/needs were presented;
- Location(s) of presentation of research gaps/needs in the report; and
- How research gaps/needs were presented (e.g., an unordered list, separated by key question, separated by type of study, as a figure/conceptual framework).

### Verification of Abstracted Information

We contacted the EPCs that produced the evidence reports selected for abstraction. We contacted the primary author of the evidence report. If it was unclear who the primary author was, or if we were not able to contact the primary author, we contacted the current director of the EPC that produced the report. We provided a summary of what was abstracted from the report and asked for any corrections and clarifications. If no explicit framework was identified in our review of the report, we asked if the EPC had implemented a process since the publication of the report. If so, the EPC was asked to provide a description of the process and to indicate when it was implemented. Each EPC was contacted via email.

## Step 3 Review of Current Practices of Organizations Involved With Evidence Synthesis

We identified organizations that develop systematic reviews or related products such as HTAs. We compiled a list by pooling together organizations from the following two sources:

- All current member organizations of the International Network of Agencies for Health Technology Assessment (INAHTA) (as listed on the INAHTA website http://www.inahta.org/ on April 27, 2010); and
- All current member organizations of the Guidelines International Network (G-I-N) from the United States (US), United Kingdom (UK), Canada, and Australia that are involved with systematic reviews, technology assessments (TA), or cost-effectiveness analyses (CEA) (as listed on the G-I-N website http://www.g-i-n.net/ on April 27, 2010).

Each organization was contacted via email and asked:

- Whether or not they have a formal process for identifying research gaps/needs;
- When the formal process (if any) for identifying research gaps/needs was implemented; and
- To provide a description of the formal process (if any).

Based on responses received from these organizations, we made independent determinations of whether the processes were formal or not. We determined processes to be formal if the organization stated that it had a formal process currently being implemented and if the process or method used was explicitly described. If formal, we assessed whether the process was directed at the identification of gaps/needs for primary research, systematic reviews, HTAs, and/or guidelines. We only included for further consideration the formal processes used by organizations for the identification of research gaps/needs for primary research.

## Step 4 Development of Framework

We considered the various elements of research gaps noted in the literature and identified by the EPCs and organizations. Based on these elements and known important aspects of research questions, we developed a framework for the identification and organization of research gaps. This framework included an explicit determination and classification of the reason(s) why each research gap exists. We developed a worksheet to facilitate the use of the framework by investigators to systematically identify, organize, and record research gaps identified during the conduct of an evidence report.

### Technical Expert Review

Once we developed the initial version of the framework, we sought feedback from two technical experts from our institution. We asked these experts to review the framework and the worksheet and to comment on the clarity and potential ease of use. We also asked them to provide general comments and suggestions for specific items that might need to be added, removed, or reworded. The framework and worksheet were refined after receipt of feedback from the technical experts.

## Step 5 Pilot Test of Framework

### Selection of EPC Evidence Reports for Pilot Test

We pilot tested the framework on two evidence reports not produced by our EPC. These reports were randomly selected from a pool of available reports from the AHRQ Website (http://www.ahrq.gov/) which met the following criteria (as of August 02, 2010): published in 2008 or later; classified as “Clinical” or “Health Care Services” (we did not consider “Technical” reports); and produced by an EPC that is part of AHRQ's EPC program between 2007 and 2012.

### Process for Pilot Test of Framework

Two team members independently applied the framework to each selected evidence report using the worksheet. The purpose was to assess the usability of the worksheet in abstracting and identifying research gaps. We decided to focus on the results sections because we wanted to simulate, as closely as possible, the process that investigators would follow in using this framework and worksheet. We envision that investigators would fill out this worksheet soon after the data synthesis phase, while writing the results section of the evidence report. Team members thus read the results sections of the reports to abstract individual research gaps. If necessary, team members read other sections of the reports. Team members also kept track of the number of key questions, number of research gaps abstracted, and number of gaps which were abstracted but could not be fit into the framework. We recorded the time taken to complete this process per evidence report. After reviewing the evidence reports and abstracting research gaps, we compared the lists of gaps identified by the two team members. We also compared the gaps we identified with those presented in the future research sections of the respective evidence reports.

## Step 6 Refinement and Finalization of Framework

We refined the framework and the worksheet based on our results from the pilot test.