# Executive Summary

## Background

Evidence reports produced by evidence-based practice centers (EPCs) have always included a future research section. However, in contrast to the explicit and transparent steps taken in the completion of a systematic review, there has not been a systematic process for the development of the future research sections.

## Objective

Our objective was to identify and pilot test a framework for the identification of research gaps.

## Methods

We used multiple resources and perspectives to help us develop a framework for the identification of research gaps. We carried out the following six steps:

- Step 1: Focused literature review
- Step 2: Review of current practices of evidence-based practices (EPCs)
- Step 3: Review of current practices of organizations involved with evidence synthesis
- Step 4: Development of framework
- Step 5: Pilot test of framework
- Step 6: Refinement and finalization of framework.

## Results

### Step 1 Focused Literature Review

Our search identified 864 unique citations. After screening, we included five articles published between 2001 and 2009. These addressed a variety of clinical conditions. The organizing principles used in these articles to identify research gaps included key questions, a care pathway, types of participants, interventions, and outcome measures, topic area, and a decision tree.

### Step 2 Review of Current Practices of Evidence-Based Practice Centers (EPCs)

#### Audit of Evidence Reports From EPCs

After stratifying by EPC, we selected 12 evidence reports (from 12 EPCs) randomly. These included 11 clinical reports and one health care services report. Our audit found only two reports that used an explicit framework/set of organizing principles for the identification of research gaps/needs. These involved the description of the gap using the population, intervention, comparison, and outcomes (PICO) framework.

#### Verification of Abstracted Information

We contacted the 12 EPCs that produced the evidence reports and sought any corrections and clarifications on what we had abstracted from those reports. We obtained feedback from each of these EPCs. Among the EPCs that had not used an explicit framework/set of organizing principles for the identification of research gaps/needs in the evidence reports that we audited, two reported that they had subsequently adopted the PICO framework to identify research gaps.

### Step 3 Review of Current Practices of Organizations Involved with Evidence Synthesis

We contacted sixty-four organizations from around the world and obtained responses from 37 (57.8%) organizations. We determined that only four (10.8%) organizations had a formal process for the identification of primary research gaps/needs. Among these organizations, two reported the use of the PICO framework, one reported the use of key questions from guidelines as the organizing principle, and one organization did not specify a framework/organizing principle for organizing research gaps.

### Step 4 Development of Framework

Based on the gathered information and for the purpose of systematically identifying and organizing research gaps, we developed a framework that includes (i) the identification of the reason(s) why the research gap exists and (ii) the characterization of the research gap using the PICOS (population, intervention, comparison, outcomes, and setting) elements. The proposed classifications for the reasons for gaps are listed below:

#### Insufficient or Imprecise Information

Insufficient information can arise if no studies are identified, if a limited number of studies are identified, or if the sample sizes in the available studies are too small to allow conclusions. An imprecise estimate has been defined as one for which the confidence interval is wide enough to include both superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that precludes a conclusion.

#### Biased Information

This includes information based on studies with significant methodological limitations or suboptimal study designs.

#### Inconsistent or Unknown Consistency Results

Inconsistent information arises when estimates of effect size from different studies do not appear to go in the same direction or if there are large or significant differences in effect sizes. If there is only one available study, even if considered large sample size, the consistency of results is unknown.

#### Not the Right Information

This could arise because results from studies might not be applicable to the population and/or setting of interest; the optimal or most important outcomes might not be assessed; or the study duration might be too short to adequately assess some important outcomes.

For each research gap, we recommend that investigative teams identify the reason(s) that most preclude conclusions from being made.

To characterize the gaps we propose identifying which element(s) in the PICOS (population [P], intervention [I], comparison [C], outcomes [O], and setting [S]) framework is (are) inadequately addressed in the evidence.

#### Worksheet

We designed a worksheet to facilitate the use of the proposed framework in the identification and organization of research gaps during evidence reviews sponsored by AHRQ (see Table A). We envision that investigators would fill out this worksheet soon after the data synthesis phase, while in the process of writing the results section of the evidence report.

Table A Step 4: Development of framework—Research gaps abstraction worksheet

### Step 5 Pilot Test of Framework

We pilot tested our framework on two randomly selected evidence reports not produced by our EPC. Some (13.6%) research gaps could not be characterized using the framework, and needed to be abstracted in free text form.

#### Challenges to use of Framework

First, the pilot test was challenging predominantly because we were not involved with the conduct of the evidence review or the writing of its results. Second, only one of the two evidence reports that we used to pilot test our framework included a strength of evidence (SOE) table for each question of interest. This meant that we could not leverage work that would already have been done in the completion of the table. Third, the two research team members who carried out the pilot test abstracted a different number of gaps because of differences in the specificity of the research gaps. Fourth, some research gaps could not be abstracted using the framework and needed to be abstracted in free text form. These gaps related to prevalence, incidence, and the effect of certain factors on prevalence and incidence.

### Step 6 Refinement and Finalization of Framework

Changes to the framework and the worksheet at this stage only involved minor formatting and clarification of the instructions.

## Discussion

We used multiple resources and perspectives including literature review, contact with other EPCs and organizations involved with evidence synthesis, and consultation with experts at our institution to develop a framework for the identification and characterization of research gaps. This framework involves two main components – identifying explicitly why the research gap exists and characterizing the research gap using widely accepted key elements. This framework facilitates the use of a systematic method to identify research gaps.

## Strengths

There are several strengths to the framework we have developed. First, it is based on widely accepted key elements (PICOS) of a well-designed research question. Second, the use of these elements will potentially make the process of identification of research gaps more systematic and therefore useful. Third, for each underlying reason for research gap we have provided the corresponding domain/element in three common evidence grading systems. Fourth, the framework characterizes the research gap, including the reason(s) for the existence of the gap.

The worksheet is simple to use and facilitates the presentation of research gaps. It is transparent and reproducible. The use of a worksheet may be beneficial in two main ways. First, it would facilitate discussion about research gaps between team members who might have written the results for different key questions. Second, the worksheet would enable investigative teams to write the future research section in a more organized and systematic manner.

We did not find consistency in how research gaps were presented during our audit of the evidence reports. We propose that while writing the future research needs sections of evidence reports, investigative teams provide adequate details of research gaps and translate them into research questions. We propose that EPCs use the following format for presenting research gaps in evidence reports.

### Key Question Number and Key Question Topic

- Research Gap Number
- Reason for Gap
- Population (P)
- Intervention (I)
- Comparison (C)
- Outcomes (O)
- Setting (S).

## Research Question

### Limitations and Future Research

We identified limited use of formal processes, including frameworks, for identifying research gaps. This prevented us from addressing whether one method for identifying research gaps is more valid than another or whether one format for presenting research gaps is more useful than another.

A limitation of the framework that we have developed is that it does not explicitly account for the specificity of research gaps. Team members could differ in terms of the number of research gaps abstracted based on whether gaps are abstracted at the level of the key question or the subquestion. We therefore suggest that a priori decisions be made about the level of specificity that should be accomplished and that investigative teams be consistent.

Our framework calls for identifying the most important reason(s) for existence of research gaps (i.e., reasons that most preclude conclusions from being made). However, there may often be more than one main reason why a research gap exists. Team members could differ on the relative importance of these reasons. More research is needed to determine if a hierarchy or a ranking system can be established to aid these decisions.

The application of the framework to retrospectively identify research gaps by our investigative team was quite challenging. We suggest that the same investigative team that synthesizes the evidence apply the framework while writing the results. We also suggest that investigative teams working on evidence reports use the SOE table for grading the evidence. If this is done, teams can leverage work completed in preparing the table to identify research gaps.

## Conclusions

We searched the literature, conducted an audit of EPC evidence reports, and sought information from other organizations involved with evidence synthesis. Despite these efforts, we identified little detail or consistency in the frameworks used to determine research gaps within systematic reviews. In general, there is no widespread use or endorsement of a specific formal process or framework for identifying research gaps using systematic reviews.

We developed a framework to facilitate the systematic identification of research gaps through the classification of where the current evidence falls short and why the evidence falls short. A worksheet was developed to facilitate the use of the framework when completing a systematic review and thus facilitate the use of a systematic process to identify research gaps.